# Availability of Guidelines

For each clinical practice guideline developed under the sponsorship of the Agency for Health Care Policy and Research (AHCPR), several versions are produced to meet different information needs.

The Guideline Report contains technical and supporting materials used in developing the guideline.

The Clinical Practice Guideline and the Quick Reference Guide for Clinicians are companion documents for use as desk-top references for clinical decisionmaking in day-to-day care of patients. Recommendations, algorithms or flow charts, tables and figures, and pertinent references are included.

A Patient's Guide, available in English and Spanish, is an informational booklet for the general public to increase consumer knowledge and involvement in health care decision making.

Guideline information also will be available for on-line retrieval through the National Library of Medicine, the National Technical Information Service, and some computer-based information systems of professional associations, nonprofit organizations, and commercial enterprises.

To order guideline products or to obtain further information on their availability, call the AHCPR Clearinghouse toll-free at (800) 358-9295; from outside the United States only, call (301) 495-3453; or write to: AHCPR Clearinghouse, P.O. Box 8547, Silver Spring, MD 20907.