# Glossary

Acute myocardial infarction:: An acute process of myocardial ischemia with sufficient severity and duration to result in permanent myocardial damage.

Angina pectoris: : A clinical syndrome typically characterized by a deep, poorly localized chest or arm discomfort that is reproducibly associated with physical exertion or emotional stress and relieved promptly by rest or sublingual NTG. The discomfort of angina is often hard for patients to describe, and many patients do not consider it to be "pain." Patients with unstable angina may have discomfort with all the qualities of typical angina except that episodes are more severe and prolonged and may occur at rest with an unknown relationship to exertion or stress. In most, but not all, patients these symptoms reflect myocardial ischemia resulting from significant underlying coronary artery disease (CAD).

Angiographically significant CAD: : CAD is typically judged "significant" at coronary angiography if there is at least a 70 percent diameter stenosis of one or more major epicardial coronary segments or at least a 50 percent diameter stenosis of the left main coronary artery. The term "significant CAD" used in this guideline does not imply clinical significance but refers only to an angiographically significant stenosis.

Anxiolytic therapy: : Treatment to counteract or diminish anxiety.

Aortic stenosis: : Narrowing of the aorta or its orifice usually due to disease of the valve.

Arrhythmia: : Irregularity or loss of rhythm of the heartbeat.

Atherosclerosis: : Nodular thickening or hardening of the layers in the wall of an artery; characterized by irregularly distributed lipid deposits in the intima of large and medium-sized arteries.

Beta blocker (β-adrenergic blocking agent): : A drug that blocks the effect of catecholamines, producing a decrease in heart rate and oxygen demand in the myocardium.

Calcium antagonist: : A drug that blocks entry of calcium into cells and inhibits the contractility of smooth muscle. The result is dilation of the blood vessels and a reduction in blood pressure.

Cardiac catheterization: : Passage of a catheter into the heart through a blood vessel leading to the heart for the purpose of measuring intracardiac pressure abnormalities, obtaining cardiac blood samples, and/or imaging cardiac structures by injection of radio-opaque dye.

Cardiac mortality: : Death due to cardiac cause.

Cardiopulmonary resuscitation: : An emergency measure to maintain a person's breathing and heartbeat when they have stopped as a result of myocardial infarction, trauma, or other disorder.

Cardiogenic shock: : Failure to maintain blood supply to the tissues because of inadequate cardiac output, such as may be caused in myocardial infarction.

Chronic obstructive pulmonary disease: : A group of conditions in which the patient has an expiratory airflow obstruction such as chronic bronchitis or emphysema.

Comorbidity: : A concomitant but unrelated pathologic or disease process, usually used to indicate coexistence of two or more disease processes.

Congestive heart failure: : Failure of the heart to maintain adequate circulation of blood.

Coronary artery bypass grafting: : Vein or artery grafted surgically to permit blood to travel from the aorta to a branch of the coronary artery at a point past an obstruction.

Coronary artery disease (CAD): : Although a number of disease processes other than atherosclerosis can involve coronary arteries, in this guideline the term CAD refers to the atherosclerotic narrowing of the major epicardial coronary arteries.

Coronary stenosis: : Narrowing or constriction of any orifices leading into or from the heart or between chambers of the heart.

Coronary thrombus: : A blood clot that obstructs a blood vessel of the heart.

Echocardiography: : Use of ultrasound in the investigation of the heart and great vessels and diagnosis of cardiovascular lesions.

Ejection fraction: : The percent of blood emptied from the ventricle by the end of a contraction of the heart.

Exercise tolerance testing: : Also referred to as a stress test, a diagnostic test in which the patient exercises on a treadmill, bicycle, or other equipment while heart activity is monitored by an ECG.

Hemodynamic instability: : Instability of the blood pressure.

Hypercholesterolemia: : Excessive cholesterol in the blood.

Hyperlipidemia: : Excessive quantity of fat (cholesterol and triglycerides) in the blood.

Hypertrophic cardiomyopathy: : Disease of the myocardium produced by the enlargement of the cells of the myocardium; often the result of increased oxygen demand in ischemic heart disease.

Hypotension: : Decrease of systolic and diastolic blood pressure below normal.

Intra-aortic balloon pump: : Use of a balloon attached to a catheter inserted through the femoral artery into the descending thoracic aorta for producing alternating inflation and deflation during diastole and systole, respectively.

Intracoronary stenting: : Use of a prosthetic metal device to provide and maintain an enlarged coronary lumen at the side of an obstructive atherosclerotic plaque.

Ischemic heart disease: : A form of heart disease whose primary manifestations result from myocardial ischemia due to atherosclerotic CAD. This term encompasses a spectrum of patients ranging from the asymptomatic preclinical phase to acute myocardial infarction and sudden cardiac death.

Left bundle branch block: : An ECG change characterized by an intraventricular conduction delay affecting the left ventricular wall and septum. Acute occurrences most commonly result from myocardial ischemia.

Left ventricular function: : Function of the main pumping chamber of the heart that receives blood from the left atrium and pumps it out into the general circulation through the aortic valve.

Left main disease: : Stenosis of the left main coronary artery.

Likelihood: : Used in this guideline to refer to the probability of an underlying diagnosis, particularly significant CAD.

Mitral regurgitation: : Abnormal systolic back flow of blood from the left ventricle into the left atrium, resulting from imperfect closure of the mitral valve.

Myocardial infarction (MI): : Damage to the heart muscle caused by occlusion of one or more of the coronary arteries.

Myocardial ischemia: : A condition in which oxygen delivery to and waste removal from the myocardium falls below normal levels with oxygen demand exceeding supply. As a consequence, the metabolic machinery of myocardial cells is impaired leading to various degrees of systolic (contractile) and diastolic (relaxation) dysfunction. Ischemia is usually diagnosed indirectly through techniques that demonstrate reduced myocardial blood flow or its consequences on contracting myocardium.

Myocardium: : The muscular wall of the heart located between the inner endocardial layer and the outer epicardial layer.

Multivessel disease: : Indicates that two or more of the coronary arteries are diseased.

Nitrate: : A drug whose metabolites produce a relaxation of vascular smooth muscle. This in turn produces a strong dilation of the veins, reducing preload and myocardial oxygen demand.

Non-Q-wave myocardial infarction: : An acute myocardial infarction that is not associated with the evolution of new Q waves on the ECG. The diagnosis of non-Q-wave myocardial infarction is often difficult to make soon after the event and is commonly made only retrospectively on the basis of elevated cardiac enzyme levels.

Percutaneous transluminal coronary angioplasty (PTCA): : A method of treating localized coronary artery narrowing using a special catheter with a cylindrical balloon surrounding it that can be inflated to dilate the narrowed vessel.

Perfusion balloon angioplasty: : A variation of PTCA in which a catheter is inserted in the artery that permits blood flow during balloon inflation.

Perfusion scan:: A test to determine the status of blood flow to an organ.

Pharmacologic stress test: : A test of heart function during intentional drug-induced stress.

Post-MI angina: : Unstable angina occurring from 1 to 60 days after an acute MI.

Pulmonary edema: : A condition, usually acute, but sometimes chronic, where fluid builds up in the lungs. This often occurs as a response to left ventricular failure in ischemic heart disease, hypertension, or aortic valve disease.

Radionuclide test: : A diagnostic test in which a radioactive substance is injected into the bloodstream and the emitted radioactivity is detected by a scanner; used to visualize the heart and vessels.

Reperfusion-eligible acute myocardial infarction: : A condition characterized by a clinical presentation compatible with acute myocardial infarction accompanied by ST-segment elevation or left bundle branch block on ECG.

Restenosis: : The recurrence of a stenosis in a coronary artery.

Revascularization: : Restoration, to the extent possible, of normal blood flow to the myocardium by surgical or percutaneous means or with removal or reduction of an obstruction as occurs when CABG or PTCA is performed.

Risk: : High, intermediate, and low risk in this guideline refer to the probability of future adverse cardiac events, particularly death or MI.

Sinus node rate: : Under normal conditions, the pacemaker function of the heart resides in the sinus node; normal heart rate.

Stenosis: : A narrowing or blockage of a coronary artery.

Sublingual: : Beneath the tongue.

Supraventricular arrhythmia: : An irregular heart beat that originates in the atria or AV node.

Thrombocytopenia: : Abnormal decrease in number of the blood platelets.

Thrombolytic therapy: : Pharmacologic treatment with a class of drugs that can break up fibrin blood clots.

Transvenous pacemaker: : Cardiac pacemaker using a pacing electrode or wire passed through a vein into the chambers of the heart that stimulates and maintains a normal heart rate; may be permanent or temporary.

Triage: : Screening and classification of sick, wounded, or injured persons to determine priority of need and proper place of treatment.

Unstable angina: : Chest pain that occurs at rest, new onset of pain with exertion, or pain that has accelerated (more frequent, longer in duration, or lower in threshold).

Variant angina: : A clinical syndrome of rest pain and reversible ST-segment elevation without subsequent enzyme evidence of acute MI. In some patients, the cause of this syndrome appears to be coronary vasospasm alone often at the site of an insignificant coronary plaque, but a majority of patients with variant angina have angiographically significant CAD.

Ventriculography: : A procedure for visualization of ventricles of the heart by x-ray after injection of a contrast material.