# Acronyms

ACLS: Advanced cardiac life support

ACME: Angioplasty Compared with Medicine [study]

ADP: Adenosine diphosphate

AHCPR: Agency for Health Care Policy and Research

aPTT: Activated partial thromboplastin time

ASA: Aspirin

AV: Atrioventricular

BB: Brain

BLS: Basic life support

CABG: Coronary artery bypass graft

CABRI: Coronary Artery Bypass Revascularization Investigation

CAD: Coronary artery disease

CCSC: Canadian Cardiovascular Society Classification

CCU: Coronary care unit

CHF: Congestive heart failure

CI: Confidence interval

CK: Creatinine kinase

COPD: Chronic obstructive pulmonary disease

DUMC: Duke University Medical Center

EAST: Emory Angioplasty Study Trial

ECG: 12-lead electrocardiogram

ED: Emergency department

EF: Ejection fraction [left ventricle]

EMT: Emergency medical transport

GABI: German Angioplasty Bypass Surgery Investigation

GI: Gastrointestinal

HDL: High-density lipoprotein

IABP: Intra-aortic balloon pump

ICU: Intensive care unit

IHD: Ischemic heart disease

IMIR: Imminent MI Rotterdam [criteria]

ISIS: International Study of Infarct Survival

IV: Intravenous

IVCD: Interventricular conduction defect

LAD: Left anterior descending coronary artery

LBBB: Left bundle branch block

LDH: Lactate dehydrogenase

LV: Left ventricular

MB: Cardiac muscle

MET: Metabolic equivalent

MI: Myocardial infarction

MM: Skeletal muscle

MR: Mitral regurgitation

NHLBI: National Heart, Lung, and Blood Institute

NTG: Nitroglycerin

PR: ECG PR segment

PTCA: Percutaneous transluminal coronary angioplasty

PTT: Partial thromboplastin time

PVD: Peripheral vascular disease

RISC: Research Group on Instability in Coronary Artery Disease

RITA: Randomized Intervention Treatment of Angina

SBP: Systolic blood pressure

TIMI: Thrombolysis in myocardial infarction

VA: Veterans Administration