# References

Aase O, Jonsbu J, Liestol K et al. Decision support by computer analysis of selected case history variables in the emergency room among patients with acute chest pain. Eur Heart J. 1993;Apr 14:433-40. [pmid: 8472704].
Ahmed WH, Bittl JA, Braunwald E. Relation between clinical presentation and angiographic findings in unstable angina pectoris, and comparison with that in stable angina. Am J Cardiol. 1993 Sep;72:544-50. [pmid: 8362768].
Amanullah A, Bevegard S, Lindvall K et al. Early exercise thallium-201 single photon emission computed tomography in unstable angina: a prospective study. Clin Physiol. 1992 Nov;12:607-17. [pmid: 1424479].
Ambrose JA, Hjemdahl-Monsen CE, Borrico S et al. Angiographic demonstration of a common link between unstable angina pectoris and non-Q-wave acute myocardial infarction. Am J Cardiol. 1988 Feb;61(4):244-7. [pmid: 3341201].
Ambrose JA, Torre SR, Sharma SK et al. Adjunctive thrombolytic therapy for angioplasty in ischemic rest angina: results of a double-blind randomized pilot study. J Am Coll Cardiol. 1992 Nov;20:197-204. [pmid: 1607525].
Antiplatelet Trialist's Collaboration. Collaborative overview of randomized trials of antiplatelet therapy. I. Prevention of death, myocardial infarction, and stroke by prolonged antiplatelet therapy in various categories of patients. Br Med J. 1994;308:81-106. [pmid: 8298418].
Arbustini E, Grasso M, Diegoli M et al. Coronary atherosclerotic plaques with and without thrombus in ischemic heart syndromes: a morphologic, immunohistochemical, and biochemical study. Am J Cardiol. 1991 Sep;68(7):36B-50B. [pmid: 1892066].
Aroesty JM, Weintraub RM, Paulin S et al. Medically refractory unstable angina pectoris. II. Hemodynamic and angiographic effects of intraaortic balloon counterpulsation. Am J Cardiol. 1979 May;43(5):883-8.
Balsano F, Rizzon P, Violi F et al. Antiplatelet treatment with ticlopidine in unstable angina. A controlled multicenter clinical trial. The Studio della Ticlopidina nell'Angina Instabile Group. Circulation. 1990 Jul;82(1):17-26. [pmid: 2194694].
Bar FW, Verheugt FW, Col J et al. Thrombolysis in patients with unstable angina improves the angiographic but not the clinical outcome. Results of UNASEM, a multicenter, randomized, placebo-controlled, clinical trial with anistreplase. Circulation. 1992 Jul;86:131-7. [pmid: 1617766].
Beckie T. A supportive-educative telephone program: impact on knowledge and anxiety after coronary artery bypass graft surgery. Heart Lung. 1989 Jan;18(1):46-55. [pmid: 2783580].
Bosch X, Theroux P, Pelletier GB et al. Clinical and angiographic features and prognostic significance of early postinfarction angina with and without electrocardiographic signs of transient ischemia. Am J Med. 1991 Nov;91(5):493-501. [pmid: 1951411].
Botker HE, Ravkilde J, Sogaard P et al. Gradation of unstable angina based on a sensitive immunoassay for serum creatine kinase MB. Br Heart J. 1991 Feb;65:72-6. [pmid: 1867950]. [pmcid: 1024495].
Braunwald E. Unstable angina. A classification. Circulation. 1989 Aug;80(2):410-4. [pmid: 2752565].
Brush JE Jr, Brand DA, Acampora D et al. Relation of peak creatine kinase levels during acute myocardial infarction to presence or absence of previous manifestations of myocardial ischemia (angina pectoris or healed myocardial infarction). Am J Cardiol. 1988 Sep;62:534-7. [pmid: 3414544].
Bugiardini R, Pozzati A, Borghi A et al. Angiographic morphology in unstable angina and its relation to transient myocardial ischemia and hospital outcome. Am J Cardiol. 1991 Mar;67:460-4. [pmid: 1998276].
Cairns JA, Gent M, Singer J et al. Aspirin, sulfinpyrazone, or both in unstable angina. Results of a Canadian multicenter trial. N Engl J Med. 1985 Nov;313(22):1369-75. [pmid: 3903504].
Cairns JA, Singer J, Gent M et al. One year mortality outcomes of all coronary and intensive care unit patients with acute myocardial infarction unstable angina or other chest pain in Hamilton, Ontario, a city of 375000 people. Can J Cardiol. 1989 Jun;5:239-46. [pmid: 2758367].
Califf RM, Harrell FE, Lee KL et al. The evolution of medical and surgical therapy for coronary artery disease: A 15-year perspective. JAMA. 1989 Apr;261(14):2077-86. [pmid: 2784512].
Califf RM, Mark DB, Harrell FE et al. Importance of clinical measures of ischemia in the prognosis of patients with documented coronary artery disease. J Am Coll Cardiol. 1988 Jan;11(1):20-6. [pmid: 3335698].
Campeau L. Grading of angina pectoris [letter]. Circulation. 1976 Sep;54(3):522-3. [pmid: 947585].
CASS Group. Coronary artery surgery study (CASS), National Heart, Lung, and Blood Institute. Killip T, Fisher LD, Mock MB, eds. Circulation. 1981;63(suppl 1). 1. 81. [pmid: 7002358].
Chaitman BR, Bourassa MG, Davis K et al. Angiographic prevalence of high-risk coronary artery disease in patient subgroups (CASS). Circulation. 1981;64:360-7. [pmid: 7249303].
Charbonnier B, Bernadet P, Schiele F et al. Intravenous thrombolysis by recombinant plasminogen activator (rt-PA) in unstable angina. A randomized multicenter study versus placebo. Arch Mal Coeur Vaiss. 1992 Oct;85:1471-7. [pmid: 1297297].
Cohen M, Hawkins L, Greenberg S et al. Usefulness of ST-segment changes in greater than or equal to 2 leads on the emergency room electrocardiogram in either unstable angina pectoris or non-Q-wave myocardial infarction in predicting outcome. Am J Cardiol. 1991 Jun;67:1368-73. [pmid: 2042567].
Daly LE, Mulcahy R, Graham IM et al. Long term effect on mortality of stopping smoking after unstable angina and myocardial infarction. Br Med J. 1983 287:324-6.
Davies MJ, Thomas A. Thrombosis and acute coronary-artery lesions in sudden cardiac ischemic death. N Engl J Med. 1984 May;310(18):1137-40. [pmid: 6709008].
Dellborg M, Gustafsson G, Swedberg K. Buccal versus intravenous nitroglycerin in unstable angina pectoris. Eur J Clin Pharmacol. 1991;41(1):5-9. [pmid: 1782977].
DePace NL, Herling IM, Kotler MN et al. Intravenous nitroglycerin for rest angina. Potential pathophysiologic mechanisms of action. Arch Intern Med. 1982 Oct;142(10):1806-9. [pmid: 6812520].
De Servi S, Ghio S, Ragni T et al. Clinical, angiographic, and prognostic findings in unstable angina. G Ital Cardiol. 1985;15(2):661-5. [pmid: 3878310].
Distante A, Maseri A, Severi S et al. Management of vasospastic angina at rest with continuous infusion of isosorbide dinitrate. A double crossover study in a coronary care unit. Am J Cardiol. 1979 Sep;44(3):533-9. [pmid: 382822].
Falk E. Morphologic features of unstable atherothrombotic plaques underlying acute coronary syndromes. Am J Cardiol. 1989 Mar;63(10):114E-20E. [pmid: 2646888].
Feinleib M. Epidemiologic evidence for cardiovascular disease initiatives in Israel and the United States. Public Health Rep. 1984 May;99(3):248-55. [pmid: 6429721].
Feinleib M, Havlik RJ, Gillum RF et al. Coronary heart disease and related procedures. National Hospital Discharge Survey data. Circulation. 1989 Jun;79(6 Pt 2):113-8.
Fiebach N, Cook EF, Lee TH et al. Outcomes in patients with myocardial infarction who are initially admitted to stepdown units: data from the Multicenter Chest Pain Study. Am J Med. 1990;89:15-20. [pmid: 2195889].
Figueras J, Lidon R, Cortadellas J. Rebound myocardial ischaemia following abrupt interruption of intravenous nitroglycerin infusion in patients with unstable angina at rest. Eur Heart J. 1991 Mar;12:405-11. [pmid: 1904029].
Fineberg HV, Scadden D, Goldman L. Care of patients with a low probability of acute myocardial infarction. Cost effectiveness of alternatives to coronary-care-unit admission. N Engl J Med. 1984 May;310:1301-7. [pmid: 6425687].
Freeman MR, Langer A, Wilson RF et al. Thrombolysis in unstable angina. Randomized double-blind trial of t-PA and placebo. Circulation. 1992 Jan;85(1):150-7.
Fuster V, Badimon L, Badimon JJ et al. The pathogenesis of coronary artery disease and the acute coronary syndromes (2). N Engl J Med. 1992 Jan;326(5):310-8. [pmid: 1728735].
Gerstenblith G, Ouyang P, Achuff SC et al. Nifedipine in unstable angina: A double-blind randomized trial. N Engl J Med. 1982 Apr;306(15):885-9. [pmid: 7038491].
Ghali JK, Cooper RS, Kowatly I et al. Delay between onset of chest pain and arrival to the coronary care unit among minority and disadvantaged patients. J Natl Med Assoc. 1993 Mar;85:180-4. [pmid: 8474130].
Gibson RS, Beller GA, Gheorghiade M et al. The prevalence and clinical significance of residual myocardial ischemia 2 weeks after uncomplicated non-Q wave infarction: a prospective natural history study. Circulation. 1986;73(6):1186-98. [pmid: 3698252].
Gibson RS, Young PM, Boden WE et al. Prognostic significance and beneficial effect of diltiazem on the incidence of early recurrent ischemia after non-Q-wave myocardial infarction: results from the Multicenter Diltiazem Reinfarction Study. Am J Cardiol. 1987 Aug;60:203-9. [pmid: 3303886].
Gillum RF, Feinleib M. Coronary heart disease in the elderly. Compr Ther. 1988 Aug;14(8):66-73. [pmid: 3048867].
Goldman L, Cook EF, Brand DA et al. A computer protocol to predict myocardial infarction in emergency department patients with chest pain. N Engl J Med. 1988 Mar;318(13):797-803. [pmid: 3280998].
Goldman L, Weinberg M, Weisberg M et al. A computer-derived protocol to aid in the diagnosis of emergency room patients with acute chest pain. N Engl J Med. 1982;307:588-96. [pmid: 7110205].
Gore JM, Goldberg RJ, Matsumoto AS et al. Validity of serum total cholesterol level obtained within 24 hours of acute myocardial infarction. Am J Cardiol. 1984 Oct;54:722-5. [pmid: 6486020].
Gortner SR, Gilliss CL, Paul SM et al. Expected and realized benefits from cardiac surgery: an update. Cardiovasc Nurs. 1989 Jul;25(4):19-24. [pmid: 2736566].
Gottlieb SO, Weisfeldt ML, Ouyang P et al. Effect of the addition of propranolol to therapy with nifedipine for unstable angina pectoris: a randomized, double-blind, placebo-controlled trial. Circulation. 1986 Feb;73(2):331-7. [pmid: 3510764].
Grambow DW, Topol EJ. Effect of maximal medical therapy on refractoriness of unstable angina pectoris. Am J Cardiol. 1992 Sep;70:577-81. [pmid: 1354937].
Graves EJ. National hospital discharge survey: annual summary, 1991. National Center for Health Statistics. Vital Heath Statistics. Series 13, Number 114. Washington: Public Health Service. 1993.
Hamm, CW, Ravkilde J, Gerhardt W et al. The prognostic value of serum troponin T in unstable angina. N Engl J Med. 1992 Jul;327(3):146-50. [pmid: 1290492].
Hargarten KM, Aprahamian C, Stueven HA et al. Prophylactic lidocaine in the prehospital patient with chest pain of suspected cardiac origin. Ann Emer Med. 1986 Aug;15(8):881-5.
Hargarten KM, Chapman PD, Stueven HA et al. Prehospital prophylactic lidocaine does not favorably affect outcome in patients with chest pain. Ann Emer Med. 1990 Nov;19(11):1274-9.
Held PH, Yusuf S, Furberg C. Calcium channel blockers in acute myocardial infarction and unstable angina: an overview. Br Med J. 1989 Nov;299:1187-92. [pmid: 2513047]. [pmcid: 1838102].
Heston TF, Lewis LM. Gender bias in the evaluation and management of acute nontraumatic chest pain. The St Louis Emergency Physicians' Association Research Group. Fam Prac Res J. 1992 Dec;12:383-9.
Hirsh J. N Engl J Med. 1991;324:565-74. [pmid: 1992314].
ISIS-2 (Second International Study of Infarct Survival) Collaborative Group. Randomized trial of intravenous streptokinase, oral aspirin, both, or neither among 17,187 cases of suspected acute myocardial infarction: ISIS-2. Lancet. 1988 Aug;2(8607):349-60. [pmid: 2899772].
Jayes RL, Beshansky JR, D'Agostino RB et al. Do patients' coronary risk factor reports predict acute cardiac ischemia in the emergency department?. J Clin Epidemiol. 1992;45:621-6. [pmid: 1607901].
Kantrowitz A, Wasfie T, Freed PS et al. Intraaortic balloon pumping 1967 through 1982: analysis of complications in 733 patients. Am J Cardiol. 1986 Apr;57:976-83. [pmid: 3515900].
Kaplan K, Davison R, Parker M et al. Intravenous nitroglycerin for the treatment of angina at rest unresponsive to standard nitrate therapy. Am J Cardiol. 1983 Mar;51(5):694-8. [pmid: 6402912].
Karlson BW, Herlitz J, Pettersson P et al. A one-year prognosis in patients hospitalized with a history of unstable angina pectoris. Clin Cardiol. 1993 May;16:397-402. [pmid: 8504573].
Karlsson JE, Berglund U, Bjorkholm A et al. Thrombolysis with recombinant human tissue-type plasminogen activator during instability in coronary artery disease: effect on myocardial ischemia and need for coronary revascularization. TRIC Study Group. Am Heart J. 1992 Dec;124(6):1419-26. [pmid: 1462894].
Katus HA, Yasuda T, Gold HK et al. Diagnosis of acute myocardial infarction by detection of circulating cardiac myosin light chains. Am J Cardiol. 1984 Nov;54:964-70. [pmid: 6496359].
Kozak LJ, Moien M. Detailed diagnoses and surgical procedures for patients discharged from short-stay hospitals. United States, 1983. National Center for Health Statistics. Series 12, No. 82 [DHHS Pub. No. (PHS) 85-1743]. Washington: Public Health Service. March 1985.
Krone RJ, Dwyer EM, Greenberg H et al. Risk stratification in patients with first non-Q wave infarction: limited value of the early low level exercise test after uncomplicated infarcts. J Am Coll Cardiol. 1989;14(1):31-7. [pmid: 2661629].
Larsson H, Areskog M, Areskog NH et al. Should the exercise test (ET) be performed at discharge or one month later after an episode of unstable angina or non-Q-wave myocardial infarction?. Int J Card Imaging. 1991;7(1):7-14. [pmid: 1753161].
Larsson H, Jonasson T, Ringqvist I et al. Diagnostic and prognostic importance of ST recording after an episode of unstable angina or non-Q-wave myocardial infarction. Eur Heart J. 1992 Feb;13:207-12. [pmid: 1555618].
Lee TH, Cook EF, Weisberg M et al. Acute chest pain in the emergency room. Identification and examination of low-risk patients. Arch Intern Med. 1985 Jan;145(1):65-9. [pmid: 3970650].
Lee TH, Cook EF, Weisberg MC et al. Impact of the availability of a prior electrocardiogram on the triage of the patient with acute chest pain. J Gen Intern Med. 1990 Sep;5:381-8. [pmid: 2231032].
Lee TH, Goldman L. Serum enzyme assays in the diagnosis of acute myocardial infarction. Ann Intern Med. 1986 Aug;105:221-33. [pmid: 3524337].
Lee TH, Juarez G, Cook EF et al. Ruling out acute myocardial infarction. A prospective multicenter validation of a 12-hour strategy for patients at low risk. N Engl J Med. 1991 May;324(18):1239-46.
Lee TH, Weisberg MC, Brand DA et al. Candidates for thrombolysis among emergency room patients with acute chest pain: true and false positive rates. Ann Intern Med. 1989 Jun;110:957-62. [pmid: 2658715].
Lewis HDJ, Davis JW, Archibald DG et al. Protective effects of aspirin against acute myocardial infarction and death in men with unstable angina. Results of a Veterans Administration Cooperative Study. N Engl J Med. 1983 Aug;309(7):396-403. [pmid: 6135989].
Lubsen J, Tijssen JG. Efficacy of nifedipine and metoprolol in the early treatment of unstable angina in the coronary care unit: findings from the Holland Interuniversity Nifedipine/metoprolol Trial (HINT). Am J Cardiol. 1987 Jul;60(2):18A-25A. [pmid: 2887097].
Luchi RJ, Scott SM, Deupree RH. Comparison of medical and surgical treatment for unstable angina pectoris. Results of a Veterans Administration Cooperative Study. N Engl J Med. 1987 Apr;316(16):977-84. [pmid: 2882420].
Madsen JK, Thomsen BL, Mellemgaard K et al. Independent prognostic risk factors for patients referred because of suspected acute myocardial infarction without confirmed diagnosis. Prognosis after discharge in relation to medical history and non-invasive investigations. Eur Heart J. 1988;9(6):611-8.
Makhoul RG, Cole CW, McCann RL. Vascular complications of the intra-aortic balloon pump: an analysis of 436 patients. Am Surg. 1993 Sep;59:564-8. [pmid: 8368661].
Mark DB, Califf R, Morris K, et al. Clinical characteristics and long-term survival of patients with variant angina. Circulation. 1984;69:880-8. [pmid: 6705163].
Mark DB, Nelson CL, Califf RM et al. The continuing evolution of therapy for coronary artery disease: initial results from the era of coronary angioplasty. Circulation, in press.
Mark DB, Shaw, L, Harrell FE et al. Prognostic value of a treadmill exercise score in outpatients with suspected coronary artery disease. N Engl J Med. 1991 Sep;325:849-53. [pmid: 1875969].
Marmur JD, Freeman MR, Langer A et al. Prognosis in medically stabilized unstable angina: early Holter ST-segment monitoring compared with predischarge exercise thallium tomography. Ann Intern Med. 1990 Oct;113:575-9. [pmid: 2400166].
May DC, Popma JJ, Black WH. In vivo induction and reversal of nitroglycerin tolerance in human coronary arteries. N Engl J Med. 1987 Sep;317:805-9. [pmid: 3114638].
McCarthy BD, Beshansky JR, D'Agostino RB et al. Missed diagnoses of acute myocardial infarction in the emergency department: results from a multicenter study. Ann Emerg Med. 1993 Mar;22(3):579-82. [pmid: 8442548].
McCarthy BD, Wong JB, Selker HP. Detecting acute cardiac ischemia in the emergency department: a review of the literature. J Gen Intern Med. 1990 Jul;5:365-73. [pmid: 2197378].
McCormick JR, Schick ECJ, McCabe CH et al. Determinants of operative mortality and long-term survival in patients with unstable angina. The CASS experience. J Thorac Cardiovasc Surg. 1985 May;89(5):683-8. [pmid: 3872968].
McNutt RA, Selker HP. How did the acute ischemic heart disease predictive instrument reduce unnecessary coronary care unit admissions?. Med Decis Making. 1988 Apr;8(2):90-4. [pmid: 3283495].
Moise A, Theroux P, Taeymans Y et al. Clinical and angiographic factors associated with progression of coronary artery disease. J Am Coll Cardiol. 1984 Mar;3(3):659-67. [pmid: 6693637].
Moss AJ, Goldstein RE, Hall WJ et al. Detection and significance of myocardial ischemia in stable patients after recovery from an acute coronary event. Multicenter Myocardial Ischemia Research Group. JAMA. 1993 May;269:2379-85. [pmid: 8479063].
Muller JE, Turi ZG, Pearle DL et al. Nifedipine and conventional therapy for unstable angina pectoris: a randomized double-blind comparison. Circulation. 1984 Apr;69:728-39. [pmid: 6365349].
National Institutes of Health. Recommendations for improving cholesterol measurement [NIH Pub. No. 90-2964]. Bethesda [MD]: National Heart, Lung, and Blood Institute, February 1990.
Nyman I, Areskog M, Areskog NH et al. Very early risk stratification by electrocardiogram at rest in men with suspected unstable coronary heart disease. J Intern Med. 1993;234:293-301. [pmid: 8354980].
Nyman I, Larsson H, Areskog M et al. The predictive value of silent ischemia at an exercise test before discharge after an episode of unstable coronary artery disease. RISC Study Group. Am Heart J. 1992 Feb;123(2):324-31. [pmid: 1736566].
Parisi AF, Folland ED, Hartigan P et al. A comparison of angioplasty with medical therapy in the treatment of single-vessel coronary artery disease. N Engl J Med. 1992 Jan;326(1):10-6. [pmid: 1345754].
Parisi AF, Khuri S, Deupree RH et al. Medical compared with surgical management of unstable angina. 5-year mortality and morbidity in the Veterans Administration Study. Circulation. 1989 Nov;80(5):1176-89. [pmid: 2680157].
Pozen MW, D'Agostino RB, Selker HP et al. A predictive instrument to improve coronary-care-unit admission practices in acute ischemic heart disease. A prospective multicenter clinical trial. N Engl J Med. 1984 May;310(20):1273-8. [pmid: 6371525].
Pryor DB, Harrell FE, Lee KL et al. Estimating the likelihood of significant coronary artery disease. Am J Med. 1983 Nov;75(5):771-80. [pmid: 6638047].
Pryor DB, Shaw L, McCants CB et al. Value of the history and physical in identifying patients at increased risk for coronary artery disease. Ann Intern Med. 1993 Jan;118:81-90. [pmid: 8416322].
Rahimtoola SH, Nunley D, Grunkemeier G et al. Ten-year survival after coronary bypass surgery for unstable angina. N Engl J Med. 1983 March;308(12):676-81. [pmid: 6600816].
Rankin JS, Newton JR Jr, Califf RM et al. Clinical characteristics and current management of medically refractory unstable angina. Ann Surg. 1984 Oct;200:457-65. [pmid: 6435550]. [pmcid: 1250511].
Raschke RA, Reilly BM, Guidry JR et al. The weight-based heparin dosing nomogram compared with a "standard care" nomogram. Ann Intern Med. 1993 Nov;119:874-81. [pmid: 8214998].
Reichek N, Priest C, Zimrin D et al. Antianginal effects of nitroglycerin patches. Am J Cardiol. 1984 Jul;54(1):1-7. [pmid: 6430053].
RISC Group. Risk of myocardial infarction and death during treatment with low dose aspirin and intravenous heparin in men with unstable coronary artery disease. Lancet. 1990 Oct;336(8719):827-30. [pmid: 1976875].
RITA Trial Participants. Coronary angioplasty versus coronary artery bypass surgery: the Randomized Intervention Treatment of Angina (RITA) trial. Lancet. 1993 Mar;341(8845):573-80. [pmid: 8094826].
Roberts KB, Califf RM, Harrell FE et al. The prognosis for patients with new-onset angina who have undergone cardiac catheterization. Circulation. 1983 Nov;68(5):970-8. [pmid: 6616798].
Rouan GW, Lee TH, Cook EF et al. Clinical characteristics and outcome of acute myocardial infarction in patients with initially normal or nonspecific electrocardiograms (a report from the multicenter chest pain study). Am J Cardiol. 1989;64:1087-92. [pmid: 2683709].
Roubin GS, Harris PJ, Eckhardt I et al. Intravenous nitroglycerine in refractory unstable angina pectoris. Aust N Z J Med. 1982 Dec;12(6):598-602. [pmid: 6819846].
Russell RO, Moraski RE, Kouchoukos N et al. Unstable angina pectoris: National cooperative study group to compare surgical and medical therapy. Am J Cardiol. 1978 Nov;42:839-48. [pmid: 309277].
Saran RK, Bhandari K, Narain VS et al. Intravenous streptokinase in the management of a subset of patients with unstable angina: a randomized controlled trial. Int J Cardiol. 1990 Aug;28(2):209-13. [pmid: 2203692].
Sawe U. Early diagnosis of acute myocardial infarction with special reference to the diagnosis of the intermediate coronary syndrome: a clinical study. Acta Med Sci. 1972;520(suppl):1-76.
Schechtman KB, Capone RJ, Kleiger RE et al. Risk stratification of patients with non-Q wave myocardial infarction. The critical role of ST segment depression The Diltiazem Reinfarction Study Research Group. Circulation. 1989 Nov;80:1148-58.
Schreiber TL, Rizik D, White C et al. Randomized trial of thrombolysis versus heparin in unstable angina. Circulation. 1992 Nov;86(5):1407-14. [pmid: 1423953].
Schroeder JS, Lamb I, Hu M et al. Coronary bypass surgery for unstable angina pectoris. Long-term survival and function. JAMA. 1977 Jun;237:2609-12. [pmid: 300813].
Scott J, Huskisson EC. Graphic representation of pain. Pain. 1976;2:175-84. [pmid: 1026900].
Scott SM, Luchi RJ, Deupree RH. Veterans Administration Cooperative Study for treatment of patients with unstable angina. Results in patients with abnormal left ventricular function. Circulation. 1988 Sep;78(3 Pt 2):I113-21. [pmid: 3261647].
Selker HP, Griffith JL, D'Agostino RB. A tool for judging coronary care unit admission appropriateness, valid for both real-time and retrospective use. A time-sensitive predictive instrument (TIPI) for acute cardiac ischemia: a multicenter study. Med Care. 1991;29:610-27. [pmid: 2072767].
Severi S, Orsini E, Marraccini P et al. The basal electrocardiogram and the exercise stress test in assessing prognosis in patients with unstable angina. Eur Heart. 1988;9(4):441-6.
Sharma GV, Deupree RH, Khuri SF et al. Coronary bypass surgery improves survival in high-risk unstable angina. Results of a Veterans Administration Cooperative study with an 8-year follow-up. Veterans Administration Unstable Angina Cooperative Study Group. Circulation. 1991 Nov;84(5 Suppl):III260-7. [pmid: 1934418].
SHEP Cooperative Research Group. Prevention of stroke by antihypertensive drug treatment in older persons with isolated systolic hypertension. Final results of the Systolic Hypertension in the Elderly Program (SHEP). JAMA. 1991 Jun;265(24):3255-64. [pmid: 2046107].
Sherman CT, Litvack F, Grundfest W et al. Coronary angioscopy in patients with unstable angina pectoris. N Engl J Med. 1986 Oct;315:913-9. [pmid: 3489893].
Silva P, Galli M, Campolo L. Prognostic significance of early ischemia after acute myocardial infarction in low-risk patients IRES (Ischemia Residua) Study Group. Am J Cardiol. 1993 May;71:1142-7. [pmid: 8480638].
Sriwatanakul K, Kelvie W, Lasagna L et al. Studies with different types of visual analog scales for measurement of pain. Clin Pharmacol Ther. 1983 Aug;34(2):234-9. [pmid: 6872418].
Swahn E, Areskog M, Berglund U et al. Predictive importance of clinical findings and a predischarge exercise test in patients with suspected unstable coronary artery disease. Am J Cardiol. 1987;59(4):208-14. [pmid: 3492907].
Telford AM, Wilson C. Trial of heparin versus atenolol in prevention of myocardial infarction in intermediate coronary syndrome. Lancet. 1981 Jun;1(8232):1225-8. [pmid: 6112564].
Thadani U, Hamilton SF, Olsen E et al. Transdermal nitroglycerin patches in angina pectoris. Dose titration, duration of effect, and rapid tolerance. Ann Intern Med. 1986 Oct;105(4):485-92. [pmid: 3092711].
Theroux P, Ouimet H, McCans J et al. Aspirin, heparin, or both to treat acute unstable angina. N Engl J Med. 1988 Oct;319(17):1105-11. [pmid: 3050522].
Theroux P, Taeymans Y, Morissette D et al. A randomized study comparing propranolol and diltiazem in the treatment of unstable angina. J Am Coll Cardiol. 1985 Mar;5(3):717-22. [pmid: 3882812].
Theroux P, Waters D, Lam J et al. Reactivation of unstable angina after the discontinuation of heparin. N Engl J Med. 1992 Jul;327(3):141-5. [pmid: 1608405].
Theroux P, Waters D, Qiu S et al. Aspirin versus heparin to prevent myocardial infarction during the acute phase of unstable angina. Circulation. 1993 Nov;88(part 1):2045-8. [pmid: 8222097].
Tierney WM, Roth BJ, Psaty B et al. Predictors of myocardial infarction in emergency room patients. Crit Care Med. 1985 Jul;13(7):526-31. [pmid: 4006491].
TIMI Study Group. The thrombolysis in myocardial infarction (TIMI) trial. N Engl J Med. 1985 Apr;312(14):932-6. [pmid: 4038784].
TIMI IIIA Investigators. Early effects of tissue-type plasmogen activator added to conventional therapy on the culprit coronary lesion in patients presenting with ischemic cardiac pain at rest. Circulation. 1993 Jan;87:38-52. [pmid: 8419023].
TIMI IIIB Investigators. Effects of tissue plasmogen activator and a comparison of early invasive and conservative strategies in unstable angina and non-Q-wave infarction: results of the TIMI IIIB trial. Circulation, in press.
Van der Does E, Lubsen J, Pool J et al. Acute coronary events in a general practice: objectives and design of the Imminent Myocardial Infarction Rotterdam Study. Heart Bull. 1976;7:91-8.
Wallentin LC. Aspirin (75 mg/day) after an episode of unstable coronary artery disease: long-term effects on the risk for myocardial infarction, occurrence of severe angina and the need for revascularization. Research Group on Instability in Coronary Artery Disease in Southeast Sweden. J Am Cardiol. 1991 Dec;18(7):1587-93.
Wasson JH, Sox HC, Neff RK et al. Clinical prediction rules. Applications and methodological standards. N Engl J Med. 1985 Sep;313(13):793-9. [pmid: 3897864].
Waters DD, Miller DD, Szlachcic J et al. Factors influencing the long-term prognosis of treated patients with variant angina. Circulation. 1983 Aug;68(2):258-65. [pmid: 6602668].
Wears RL, Li S, Hernandez JD et al. How many myocardial infarctions should we rule out?. Ann Emer Med. 1989 Sep;18:953-63.
White LD, Lee TH, Cook EF et al. Comparison of the natural history of new onset and exacerbated chronic ischemic heart disease. The Chest Pain Study Group. J Am Coll Cardiol. 1990 Aug;16(2):304-10. [pmid: 2373809].
Wilcox I, Freedman SB, McCredie RJ et al. Risk of adverse outcome in patients admitted to the coronary care unit with suspected unstable angina pectoris. Am J Cardiol. 1989 Oct;64(14):845-8. [pmid: 2801551].
Williams DO, Kirby MG, McPherson K et al. Anticoagulant treatment of unstable angina. Br J Clin Prac. 1986 Mar;40(3):114-6.
Young GP, Hedges JR, Gibler WB et al. Do CK-MB results affect chest pain decision making in the emergency department?. Ann Emer Med. 1991 Nov;20:1220-8.
Younis LT, Byers S, Shaw L et al. Prognostic value of intravenous dipyridamole thallium scintigraphy after an acute myocardial ischemic event. Am J Cardiol. 1989;64(3):161-6. [pmid: 2741825].
Yusuf S, Collins R, MacMahon S et al. Effect of intravenous nitrates on mortality in acute myocardial infarction: an overview of the randomized trials. Lancet. 1988 May;1(8594):1088-92. [pmid: 2896919].
Yusuf S, Pepine CJ, Garces C et al. Effect of enalapril on myocardial infarction and unstable angina in patients with low ejection fractions. Lancet. 1992 Nov 14;340(8829):1173-8. [pmid: 1359258].
Yusuf S, Wittes J, Friedman L. Overview of results of randomized clinical trials in heart disease. II. Unstable angina, heart failure, primary prevention with aspirin, and risk factor modification. JAMA. 1988 Oct;260(15):2259-63. [pmid: 3050165].
Zhu YY, Chung WS, Botvinick EH et al. Dipyridamole perfusion scintigraphy: The experience with its application in one hundred seventy patients with known or suspected unstable angina. Am Heart J. 1991 Jan;121:33-43. [pmid: 1985375].