# Essential Definitions Related to Unstable Angina

Angina pectoris:: A clinical syndrome typically characterized by a deep, poorly localized chest or arm discomfort that is reproducibly associated with physical exertion or emotional stress and relieved promptly by rest or sublingual nitroglycerin. The discomfort of angina is often hard for patients to describe, and many patients do not consider it to be "pain." In most but not all patients, these symptoms reflect myocardial ischemia resulting from significant underlying coronary artery disease.

Coronary artery disease (CAD):: While a number of disease processes other than atherosclerosis can involve coronary arteries, in this guideline the term CAD refers to the atherosclerotic narrowing of the major epicardial coronary arteries.

Angiographically significant CAD:: CAD is typically judged "significant" at coronary angiography if there is at least a 70 percent diameter stenosis of one or more major epicardial coronary segments or at least a 50 percent diameter stenosis of the left main coronary artery. The term "significant CAD" used in this guideline does not imply clinical significance but refers only to an angiographically significant stenosis.

Myocardial ischemia:: A condition in which oxygen delivery to and waste removal from the myocardium falls below normal levels with oxygen demand exceeding supply. As a consequence, the metabolic machinery of myocardial cells is impaired leading to various degrees of systolic (contractile) and diastolic (relaxation) dysfunction. Ischemia is usually diagnosed indirectly through techniques that demonstrate reduced myocardial blood flow or its consequences on contracting myocardium.

Ischemic heart disease:: A form of heart disease whose primary manifestations result from myocardial ischemia due to atherosclerotic CAD. This term encompasses a spectrum of patients ranging from the asymptomatic preclinical phase to acute myocardial infarction and sudden death.

Acute myocardial infarction (MI):: An acute process of myocardial ischemia with sufficient severity and duration to result in permanent myocardial damage.

Reperfusion-eligible acute MI:: A condition characterized by a clinical presentation compatible with acute MI accompanied by ST-segment elevation or left bundle branch block on electrocardiogram.

Non-Q-wave MI:: An MI that is not associated with the evolution of new Q waves on the ECG. The diagnosis of non-Q-wave MI is often difficult to make soon after the event and is commonly made only retrospectively on the basis of elevated cardiac enzyme levels.

Post-MI angina:: Unstable angina occurring from 1 to 60 days after an acute MI.

Likelihood:: Used in this guideline to refer to the probability of an underlying diagnosis, particularly significant CAD.