# Panel Members

- Eugene Braunwald, MD
- (Panel Chair) Hersey Professor of the Theory and Practice of Medicine Chairman, Department of Medicine
- Harvard Medical School
- Brigham & Women's Hospital
- Boston, MA
- Jay Brown, MD (Deceased)
- Chief, Division of Cardiology
- Harlem Hospital Center
- Clinical Associate Professor of Medicine
- Columbia University College of Physicians and Surgeons
- New York, NY
- Leslie Brown, MPH, JD
- Deputy Director
- Division of Adult Health Promotion
- Department of Environment, Health, and Natural Resources State of North Carolina
- Raleigh, NC
- Melvin D. Cheitlin, MD
- Chief, Cardiology Division
- San Francisco General Hospital
- Professor of Medicine
- University of California, San Francisco School of Medicine
- San Francisco, CA
- Craig A. Concannon, MD
- Chief of Staff
- Mitchell County Hospital
- Clinical Professor
- University of Kansas School of Medicine, Wichita
- Wichita, KS
- Marie Cowan, RN, MS, PhD
- Associate Dean of Research and Practice
- Professor of Physiological Nursing
- University of Washington School of Nursing
- Seattle, WA
- Conan Edwards, PhD
- Volunteer
- American Association of Retired Persons
- Madison, WI
- Valentin Fuster, MD, PhD
- Arthur M. and Hilda A. Master Professor of Medicine
- Director, Cardiovascular Institute Vice Chairman,
- Department of Medicine Mount Sinai Medical Center
- New York, NY
- Lee Goldman, MD
- Professor of Medicine
- Harvard Medical School
- Chief Medical Officer
- Brigham & Women's Hospital
- Boston, MA
- Lee A. Green, MD, MPH
- Assistant Professor
- Department of Family Practice University of Michigan Medical School
- Lecturer in Health Services Management and Policy
- University of Michigan School of Public Health
- Ann Arbor, MI
- Cindy L. Grines, MD
- Director Cardiac Catheterization Laboratory
- William Beaumont Hospital
- Royal Oak, MI
- Bruce W. Lytle, MD
- Surgeon Department of Thoracic and Cardiovascular Surgery
- Cleveland Clinic Foundation
- Cleveland, OH
- Kathleen M. McCauley, PhD, RN, CS
- Assistant Professor of Cardiovascular Nursing
- University of Pennsylvania School of Nursing
- Cardiovascular Clinical Specialist
- Hospital of the University of Pennsylvania
- Philadelphia, PA
- Alvin I. Mushlin, MD, ScM
- Professor of Community Medicine and Medicine
- University of Rochester Medical Center
- Rochester, NY
- Gregory C. Rose, MD
- Director, Mobile Cardiac Care Unit
- Wake Medical Center
- Raleigh, NC
- Earl E. Smith III, MD
- Medical Director and Chief Emergency Department
- Erlanger Medical Center
- Clinical Instructor Department of Medicine
- Chattanooga Unit, University of Tennessee College of Medicine
- Chattanooga, TN
- Julie A. Swain, MD
- Chief, Division of Cardiovascular Surgery Vice Chairman, Department of Surgery
- University of Nevada School of Medicine, Las Vegas
- Las Vegas, NV
- Eric J. Topol, MD
- Professor of Medicine Cleveland Clinic Health Sciences Center,
- Ohio State University
- Chairman, Department of Cardiology
- Cleveland Clinic Foundation
- Cleveland, OH
- James T. Willerson, MD
- Edward Randall III Professor Chairman, Department of Internal Medicine
- University of Texas Health Science Center, Houston
- Medical Director
- Texas Heart Institute
- Houston, TX

## Duke University Participants

### Project Oversight

- Robert H. Jones, MD
- Project Director Mary and Deryl Hart
- Professor of Surgery
- Daniel B. Mark, MD, MPH
- Project Co-Director
- Author/Editor
- Associate Professor Division of Cardiology
- Nancy Archibald, MHA, MBA
- Project Manager
- Vanessa Moore
- Staff Assistant

### Statistical Analysis

- L. Richard Smith, PhD
- Biostatistician
- Assistant Professor Division of Experimental Surgery
- Karen Kesler, MS
- Biostatistician

### Consultants

- Robert M. Califf, MD
- Associate Professor Division of Cardiology
- Director, Cardiac Care Unit
- David B. Pryor, MD
- Associate Professor Division of Cardiology

### Literature Review

- David B. Matchar, MD
- Methodologist
- Associate Professor
- Director,
- Center for Health Policy Research and Education
- Robert H. Sprinkle, MD, PhD
- Assistant Professor
- Literature Review Manager
- Center for Health Policy Research and Education
- Victor Hasselblad, PhD
- Statistician/Meta-analyst
- Associate Professor
- Center for Health Policy Research and Education
- Leslee Shaw, PhD
- Reviewer
- John S. Pauk, MD, MPH
- Reviewer
- Dean D. Blakeley, MD
- Reviewer

### Computer Support

- Donald F. Fortin, MD
- Medical Consultant
- Assistant Professor Division of Cardiology
- Director, Cardiac Imaging Center
- J. Douglass Hanemann
- Technical Consultant