# Acknowledgments

The Clinical Practice Guideline, Unstable Angina: Diagnosis and Management, is the result of the dedicated efforts of many individuals. The expert panel and contract staff would like to acknowledge those who contributed both their expertise and advice.

AHCPR project officer Barbara Fleming, MD, PhD, spent countless hours with both the panel and staff advising on the guideline process and acting as liaison with other organizations. Her enthusiasm and energy have been appreciated by all.

Michael J. Horan, MD, ScM, Director of the Division of Heart and Vascular Diseases at the National Heart, Lung, and Blood Institute, attended all panel meetings and provided comments on both the clinical practice guideline and patient guide.

Editing and production of this guideline was facilitated by Mary L. Grady, a public affairs specialist within AHCPR's Center for Research Dissemination and Liaison, who provided valuable comments throughout the production process.

Beverly Murphy, Associate Librarian and Head of Reference Services at the Duke University Medical Center Library, constructed and performed database searches of the literature.

The initial review of the literature was aided by the help of Drs. Dariuz Borkowski, Dariuz Luczak, Dariuz Paczkowski, Mariusk Pytkowski, and Andrzej Wiernikowski visiting Duke University from the Instytut Kardiologii, Warsaw, Poland.

The expert panel and Duke staff also thank the individuals who participated in focus group testing of the consumer guide.