# Foreword

Unstable angina is a transitory clinical syndrome usually associated with an increased tempo or intensity of symptoms that are thought to be indicative of coronary artery disease accompanied by an increased risk of cardiac death and myocardial infarction. This common condition accounts for a significant amount of disability and death. In 1991 alone, the National Center for Health Statistics reported 570,000 hospitalizations for this condition, resulting in 3.1 million hospital days.

This Clinical Practice Guideline provides recommendations and supporting evidence for all aspects of the diagnosis and treatment of unstable angina in both the inpatient and outpatient settings. The management of patients with acute myocardial infarction or stable angina is addressed only when these related conditions border indistinguishably with unstable angina. The panel assumes that medical practitioners will use general medical knowledge and clinical judgment in flexibly applying the general principles and specific recommendations of this document to the management of individual patients with unstable angina.

The guideline is written to be directly applicable to patient care. An initial chapter defines and provides background information about unstable angina. Subsequent chapters outline patient management in seven discrete phases: initial evaluation and treatment, outpatient care, intensive medical management, nonintensive medical management, noninvasive testing, cardiac catheterization and myocardial revascularization, and hospital discharge care. Chapter organization reflects common stages of care determined by requirements for specialized facilities and personnel but is not meant to constrain a management sequence for all patients. Appropriate chapters should be applied as patients enter, exit, or re-enter specific phases of their illness. The goal of patient counseling sections included in each chapter is to foster a sense of partnership and reasonable expectation between the patient and patient advocate and the health care team.

The diagnosis of unstable angina implies risk of cardiac injury and death. Needlessly overcautious management strategies initiated in an attempt to eliminate all risks often spawn secondary risks and are discouraged both for this reason and because of the extra cost burden they impose. Diagnostic and therapeutic strategies recommended are those most likely to maximize benefits given the current state of medical knowledge. However, adherence to this or any other guideline will not ensure perfect medical outcomes. Application of the most carefully reasoned clinical judgment based on current medical knowledge cannot eliminate all risk in the management of patients with unstable angina.

- Unstable Angina Guideline Panel