# [Inside Front Cover]

The Agency for Health Care Policy and Research (AHCPR) was established by Congress in December 1989 (Public Law 101-239) to improve the availability, quality, appropriateness, and effectiveness of health care services. Specific offices within AHCPR support medical effectiveness research and disseminate new health care information to health care providers, policymakers, and the public. The Office of the Forum for Quality and Effectiveness in Health Care (the Forum) within AHCPR has primary responsibility for facilitating the development and periodic updating of guidelines for prevention and management of clinical conditions. Guidelines are available in formats suitable for health care practitioners and consumers.

The National Heart, Lung, and Blood Institute (NHLBI) supports biomedical research and patient and professional education on health care. The NHLBI coordinated development of several professionally oriented clinical guidelines, including ones on high blood pressure and high blood cholesterol. Recognizing the importance of unstable angina, NHLBI has enthusiastically collaborated with AHCPR as a partner in the development of this clinical practice guideline.

AHCPR and NHLBI support for the development of this clinical practice guideline was awarded to Duke University Medical Center in October, 1992. A 19-member panel was created that included physicians (cardiology and cardiothoracic surgery and emergency, family, and internal medicine), cardiovascular nurse specialists, a public health representative, and a consumer representative. This guideline is based on evidence assembled from the published literature and data base analysis performed by the Duke team and presented for review and recommendations by this panel of experts. These recommendations outline a comprehensive care plan for patients with unstable angina. Peer and pilot review further refined this evidence-based document into this clinical practice guideline. The guideline is intended for use by a broad range of health care practitioners, including cardiologists, cardiac surgeons, family practitioners, internists, and nurses.

This first edition of Unstable Angina: Diagnosis and Management, Clinical Practice Guideline No. 10, will be updated as new evidence emerges. Comments on this guideline are welcome and should be addressed to: Director, Office of the Forum, Agency for Health Care Policy and Research, Willco Building, Suite 310, 6000 Executive Boulevard, Rockville, MD 20852.