# Guideline: Noninvasive Testing

## Background

The entire process of managing patients with unstable angina requires ongoing risk stratification. Much prognostic information of value derives from the initial assessment and the patient's subsequent course over the first few days of management, as described in Chapters 3 and 4. In many cases, noninvasive stress testing provides a useful supplement to these clinically based risk assessments.

However, some patients, such as those with rest angina and ECG-documented ischemia, have such a high likelihood of CAD and risk of adverse events that noninvasive risk stratification would not be likely to identify a subgroup with sufficiently low risk to merit noninterventional strategies. Other patients are not willing to consider interventional treatment or have severe complicating illnesses or advanced age so that referral for revascularization would not be reasonable. Still other patients may be felt to have a very low likelihood of CAD after their initial complete clinical evaluation with an associated risk of cardiac events so low that no positive test finding would prompt consideration of catheterization and myocardial revascularization. All patients who do not fall into one of the above exception categories are reasonable candidates for risk stratification by noninvasive testing (see Figure 9).

Figure 9: Patient flow: Noninvasive testing

## Objectives of Care

The goals of noninvasive testing in a patient with unstable angina who has recently been stabilized are to estimate the subsequent prognosis, especially for the next 3 to 6 months, to decide what additional tests and adjustments in therapy are required based on this prognosis, and to provide the patient with the information and reassurances necessary to return to a lifestyle as full and productive as possible.

## Approach to Care Objectives

### Selection of Noninvasive Tests

Recommendation: Exercise or pharmacologic stress testing should generally be an integral part of the outpatient evaluation of low-risk patients with unstable angina. In most cases, testing should be done within 72 hours of presentation (strength of evidence = B).

Recommendation: Unless cardiac catheterization is indicated, noninvasive exercise or pharmacologic stress testing should be performed in low- or intermediate-risk patients (see Table 7) hospitalized with unstable angina who have been free of angina and CHF for a minimum of 48 hours (strength of evidence = B).

Recommendation: Choice of initial stress testing modality should be based on an evaluation of the patient's resting ECG, his or her physical ability to perform exercise, and the local expertise and technologies available. In general, the exercise treadmill test should be the standard mode of stress testing employed in patients with a normal ECG who are not taking digoxin. Patients with widespread resting ST depression (>=1 mm), ST changes secondary to digoxin, LV hypertrophy, LBBB/significant intraventricular conduction deficit (IVCD), or pre-excitation usually should be tested using an imaging modality. Patients unable to exercise due to physical limitations (e.g., arthritis, amputation, severe peripheral vascular disease [PVD], severe COPD, general debility) should undergo pharmacologic stress testing in combination with an imaging modality (strength of evidence = B).

Recommendation: Choice among the different imaging modalities that can be used with exercise or pharmacologic stress testing should be based primarily on the local expertise available to perform and interpret the study (strength of evidence = C).

Noninvasive functional or stress testing refers to a series of provocative tests that use either exercise or pharmacologic means to detect ischemia or inhomogeneity in myocardial blood flow due to obstructive CAD. The exercise tests are based on the principle of using a progressive physiologic stress (usually treadmill or bicycle exercise) to increase myocardial work and oxygen demand while using some method (ECG, function, perfusion) to document objective evidence of ischemia. Provocation of ischemia at a low workload (e.g., >=5 to 6 metabolic equivalents [METs]) signifies a high-risk patient who would generally merit referral to cardiac catheterization. On the other hand, attainment of a higher workload (e.g., >=5 to 6 METs) without ischemia is associated with a better prognosis, and many such patients can be safely managed conservatively. Other patients, including those who tolerate only a low workload but have no evident ischemia or those who develop ischemia at a high workload, represent an intermediate-risk group for whom several reasonable strategies can be proposed.

Pharmacologic stress testing provides an important complement to exercise testing, particularly for the subset of patients who are unable to exercise ( Zhu, Chung, Botvinick et al., 1991). The IV-administered coronary vasodilators such as dipyridamole decrease coronary vascular resistance and thus substantially increase coronary flow. Where significant epicardial coronary stenosis exists, the increase in flow is limited relative to myocardial segments supplied by nonobstructed coronary arteries. This flow discrepancy is routinely evaluated with perfusion scintigraphy. Occasionally, these agents produce ischemia by provoking an endocardial to epicardial steal and consequent diminished endocardial blood flow in the territory of a critical coronary stenosis. In contrast, dobutamine stress testing with measurement of cardiac function or perfusion acts by increasing myocardial oxygen demand in a fashion similar to exercise.

The greatest experience with these agents is in patients who are unable to exercise. In general, their prognostic value appears equivalent to exercise testing with imaging although there are few direct comparison studies of prognostic stratification with the two approaches. However, the known prognostic information derived from maximal exercise level attained argues for use of pharmacologic stress testing as an alternative to exercise testing only for specific indications.

No empirical data or theoretical arguments have yet established that LV function during exercise or pharmacologic stress provides more valuable prognostic information than a perfusion scan or vice versa. Both the extent of CAD and the degree of LV dysfunction are important for selection of appropriate therapy. Studies directly comparing prognostic information from multiple noninvasive tests for ischemia in patients after stabilization of unstable angina are hampered by small sample size ( Amanullah, Bevegard, Lindvall et al., 1992; Marmur, Freeman, Langer et al., 1990).

Two relatively large studies addressed the prognostic value of exercise testing in unstable angina to predict death and MI. The Multicenter Myocardial Ischemia Research Group recently reported the results of a 23-month followup study of the prognostic value of noninvasive testing in 936 stable CAD patients who had an MI (70%) or unstable angina (30%) hospitalization within the 6-month period prior to testing ( Moss, Goldstein, Hall et al., 1993). Noninvasive testing involved rest, ambulatory, and exercise ECG and stress thallium-201 scintigraphy. The outcome event tested was a composite of death (n=22), nonfatal MI (n=53), or unstable angina (n=125). In the primary analysis, only ST depression on the resting ECG was an independent prognostic factor. Both exercise ECG ST-depression (p=0.29) and reversible thallium defects (p=0.05) showed univariate trends towards a worse prognosis. Ambulatory ECG changes were not significant predictors of outcome in this population (p=0.93). Additional prespecified analyses revealed that the combination of exercise ST depression >0.10 mV and an exercise duration <9 minutes (modified Bruce protocol) identified patients at a 3.4-fold (<6 minutes) to 1.9-fold (6-9 minutes) increase in risk of cardiac events. With the exercise thallium, a reversible defect and increased lung thallium uptake indicated a 2.8-fold increase in risk; a reversible defect alone signified a 1.2-fold increase in risk.

The RISC study group evaluated the use of predischarge symptom-limited, bicycle exercise testing in 740 men admitted with unstable angina (51%) or non-Q-wave MI (49%) ( Nyman, Larsson, Areskog et al., 1992). Multivariate analysis showed that the extent of ischemic ST depression (number of positive leads) and low maximal workload were independent predictors of 1-year, infarct-free survival.

In addition to these two large studies, six studies of patients with unstable angina report at least 10 cardiac deaths and/or MIs during followup Table 10. These studies permit comparison of the effectiveness of exercise electrocardiogram and exercise or dipyridamole thallium-201 for risk stratification. The total annualized risk of cardiac events in each study is depicted in Figure 10, with the individual studies arranged from left to right in ascending order of risk. This arrangement places studies in populations at lower risk on the left and at higher risk of subsequent event on the right. The annualized percentage risk in the high- and low-risk groups stratified by a positive or negative noninvasive test is plotted using criteria defined as optimal for each study. All three studies show similar accuracy in dichotomizing the total population into low- and high-risk subgroups.

Figure 10: Noninvasive testing for risk stratification in patients with unstable angina

Source: Studies summarized in Table 10.

Table 10. Noninvasive studies in patients with unstable angina reporting at least 10 cardiac events (cardiac death or myocardial infarction) during followup

| Study | Inclusion criteria | Low risk | High risk
A | Moss, Goldstein, Hall et al, 1993 | 30% Unstable angina 26% Non-Q-wave MI | 893 | 23
B | Swahn, Areskog, Berglund et al, 1987 | All unstable angina | 247 | 145
C | Severi, Orsini, Marraccini et al, 1988 | All unstable angina | 199 | 175
D | Madsen, Thomsen, Mellemgaard et al, 1988 | All unstable angina | 118 | 98
E | Nyman, Larsson, Aresko et al, 1992 | All unstable angina | 366 | 374
F | Krone, Dwyer, Greenberg et al, 1989 | All non-Q-wave MI | 85 | 7
A | Moss, Goldstein, Hall et al, 1993 | 30% Unstable angina 26% Non-Q-wave MI | 876 | 20
D | Madsen, Thomsen, Mellemgaard et al, 1988 | All unstable angina | 129 | 29
G | Gibson, Beller, Gheorghiade et al, 1986 | 36% Non-Q-wave MI 64% MI | 133 | 108
H | Younis, Byers, Shaw et al, 1989 | 58% Unstable angina 42% MI | 14 | 54

In low-risk patients, it is unclear that an imaging modality adds importantly to a standard treadmill test. Thus, selection of the test to use with an individual patient should rest primarily on patient characteristics, knowledge of local availability, and interpretation expertise. Because of simplicity, lower cost, and widespread familiarity with performance and interpretation, the standard ECG treadmill is the most reasonable test to select in patients able to exercise who have a normal resting ECG. Patients with an abnormal baseline ECG that would interfere with interpretation of the exercise results should have an imaging modality added to their test. Patients unable to exercise should have a pharmacologic stress test. The optimal testing strategy in women remains less well defined than in men. All major forms of exercise testing have been reported as less accurate for diagnosis in women. At least a portion of the lower reported accuracy derives from a lower pretest likelihood of CAD in populations of women compared with men. The relative accuracy of noninvasive testing for prognosis in women and men has not been adequately studied. Until data are reported to clarify this issue, it is reasonable to use noninvasive testing for prognosis in women as freely as in men with proper consideration of the influence of sex on the pretest likelihood of CAD.

The stress test using a standard protocol can be performed as soon as appropriate indications are present and the patient has stabilized clinically. In 1991, Larsson, Areskog, Areskog and colleagues compared the results of a symptom-limited exercise test performed before discharge at 3 to 7 days after an episode of unstable angina or non-Q-wave infarction with the results of a similar test 1 month later in 189 patients. The diagnostic and prognostic value of both tests was similar, but the earlier test identified events occurring over the first month which represented one-half of all events during the first year. This study illustrates the importance of early noninvasive testing for risk stratification of patients with unstable angina.

### Use of Noninvasive Test Results in Patient Management

Recommendation: Patients with a low-risk exercise test result (predicted average annual cardiac mortality <1%/year) can be managed medically without need for referral to cardiac catheterization (strength of evidence = B).

Recommendation: Patients with a high-risk exercise test result (predicted average annual cardiac mortality >=4%/year) should be referred for prompt cardiac catheterization (strength of evidence = B).

Recommendation: Patients with intermediate-risk exercise test results (predicted average annual cardiac mortality 2-3%/year) should be referred for additional testing, either cardiac catheterization or an (alternative) exercise imaging study (strength of evidence = C).

Recommendation: A stress test result of intermediate risk combined with evidence of LV dysfunction should prompt referral to cardiac catheterization (strength of evidence = C).

Noninvasive tests are most useful in patient management decisions when risk can be stated in terms of events over time. A large population of patients must be studied to derive and test equations needed to accurately predict risk for individual patients. No noninvasive study has been reported in a sufficient number of patients after stabilization of unstable angina to develop and test the accuracy of a multivariable equation to report test results in terms of absolute risk. Therefore, data borrowed from studies of patients with stable angina must be used if risk is to be reported as events/time. Although the pathologic process evoking ischemia may be different in the two subgroups, it is likely that use of prognostic nomograms derived on groups of patients with stable angina would also be predictive of risk in patients with recent unstable angina after stabilization. Using this untested assumption, the much larger literature derived from populations that include patients with both stable and unstable angina provides equations for risk stratification which convert physiologic changes observed during noninvasive testing into statements of risk expressed as events over time.

An exercise treadmill is the most commonly used stress test and has the largest reported experience for use in patients with unstable angina. A nomogram useful to convert results from this test into a statement of mortality has been derived on a large sample of patients with CAD (Figure 11). Even though use of this nomogram to quantitate risk from results of treadmill examinations may understate risk in patients with unstable angina, this approach provides more clinically useful information than a simple normal/abnormal reading ( Mark, Shaw, Harrell et al., 1991).

Figure 11: Nomogram of the prognostic relations embodied in the treadmill score

## Patient Counseling

Results of a noninvasive test should be reported to the patient, his or her family, and advocate in language they can understand, and the test results should be used by the patient and the doctor to determine the advisability of cardiac catheterization and the need for adjustments in the patient's medical regimen.

## Medical Record

The medical record should include:

- Indications for test.
- Type of test performed.
- Summary of test results including ECG changes, symptoms, hemodynamic changes, reason for termination (exercise tests).
- Test complications.
- Summary of posttest prognosis (low, intermediate, high risk or probability of adverse-event calculation).