# Guideline: Progression to Nonintensive Medical Management

## Introduction

High-risk and some intermediate-risk unstable angina patients will be moved to the nonintensive phase after 1 or more days of intensive management and stabilization. Some of these latter patients will have undergone cardiac catheterization, and some also will have had one or more revascularization procedures. Other intermediate-risk unstable angina patients may be admitted initially to a monitored intermediate care unit until the diagnosis of MI can be excluded and it is clear that the patient's symptoms are adequately controlled on medical therapy. These patients then enter the nonintensive phase of management. Still other intermediate-risk and some low-risk patients may be admitted directly to a regular hospital bed with telemetry capabilities, thereby proceeding directly to the nonintensive phase. Management of the nonintensive phase is described in this chapter (see Figure 8).

Figure 8: Patient flow: Progression to nonintensive medical management

## Objectives of Care

Transfer out of the intensive care phase is an important indicator that the patient has progressed to a lower risk state. At this point, emphasis shifts from acute stabilization to design of a maintenance medical regimen that will suppress reactivation of acute disease activity. In addition, a major focus is placed on risk stratification with primary goals of assessing the future risk of adverse cardiac events, the sufficiency of medical therapy in controlling symptoms, and the need for diagnostic cardiac catheterization and revascularization. Use of noninvasive testing is detailed in Chapter 6, and indications for catheterization and revascularization are described in Chapter 7. This chapter will describe the general care of patients who have reached the nonintensive phase of care. By this point in the hospital course, most patients with acute MI have been identified; their subsequent management is outside the scope of this guideline.

## Approach to Care Objectives

Once patients reach the nonintensive phase of management, reasons for continued hospitalization include optimization of medical therapy, evaluation of the propensity for recurrent ischemia or ischemic complications, and risk stratification to determine the need for catheterization and revascularization. Continuous monitoring of the ECG at this phase is generally unnecessary. All patients should be instructed to notify nursing personnel immediately if chest discomfort recurs. Recurrent ischemic episodes should prompt a brief nursing assessment and an emergent ECG and generally should be brought to the attention of a physician. The patient's medical regimen should be reevaluated and doses of anti-ischemic agents should be increased as tolerated. Patients who have pain or ECG evidence of ischemia increasing in severity for > 20 minutes and unresponsive to NTG should be transferred to the intensive management phase protocol. Patients who respond to sublingual NTG do not need to be transferred. However, a second recurrence of chest pain of at least 20 minutes duration in the setting of appropriate medical therapy should prompt return of the patient to a monitored environment and the management steps outlined in the intensive management phase.

In general, patients reaching this phase would be referred within 1 to 2 days either for noninvasive functional testing or for cardiac catheterization. Selection of the appropriate strategy of risk stratification is discussed in Chapters 6 and 7. Patients can be considered ready for discharge from the hospital when their evaluation is complete and an appropriate outpatient therapeutic regimen is established.

## Patient Counseling

Recommendation: During this phase, the patient should gradually progress under the observation of the health care team to a level of activity commensurate with the amount of activity required to perform activities of daily living (strength of evidence = C).

Recommendation: In this phase, the patient and his or her family should begin to work toward risk-factor modification goals (strength of evidence = C).

Steps to move the patient towards readiness for hospital discharge should be initiated during this phase. These steps include instruction on home diet and exercise, physical activity, resumption of sexual relations, return to work, and resumption of driving and other usual activities. In addition, detailed discussions should be conducted with the patient, his or her family, and the patient's advocate to review the events since presentation and their significance, current status, diagnostic and therapeutic options, and general prognosis.

The slower pace of this phase of the patient's hospitalization, in contrast to early stabilization and intensive care, offers the most appropriate time for CAD education. During the initial phase of the hospitalization, the patient may be in much pain, under sedation, or generally too anxious to retain the information. Likewise, immediately before discharge the patient may be distracted by preparations for going home.

## Medical Record

The following information should be added to the medical record during this phase of care:

- Medications at the beginning and conclusion of this phase of care.
- The number, severity, and duration of ischemic episodes.
- Complications occurring during this phase.
- Evaluation of the patient's understanding of recommended lifestyle changes and an assessment of the patient's willingness to adhere to recommendations.

## Duration of Nonintensive Medical Management

The nonintensive phase of management begins with ICU or intermediate care unit transfer and extends until hospital discharge. During this phase, risk stratification will be completed, and many patients will undergo cardiac catheterization and revascularization procedures. Thus, low-risk patients not requiring further intervention may be discharged in 1 to 2 days, but patients with complicated cases or those requiring CABG may require an additional week or more of hospitalization.