# Glossary

## General Terms

AHCPR: : Agency for Health Care Policy and Research; Federal agency established in 1989.

Best evidence synthesis: : Evidence based on the best evidence principle as used in law, in which the same evidence that would be essential in one case might be disregarded in a second case because better evidence becomes available.

Case study design: : A nonexperimental study that extensively explores a single unit (a unit may be a person, family, or group) or a very small number of units.

Descriptive study: : A nonexperimental study in which variables or subject characteristics are examined as they naturally occur for the purpose of describing or comparing samples or examining relationships among a set of variables.

Experimental study: : (Randomized controlled trial or randomized clinical trial) An experiment that uses random assignment to create treatment and control groups so that changes can be inferred or attributed to the experimental treatment.

Meta-analysis: : The process of combining the results of several related studies to obtain more reliable conclusions.

Peer review: : Evaluation of the present guideline document by an interdisciplinary panel of experts using the Institute of Medicine (Field and Lohr, 1990) attributes of clinical practice guidelines as evaluation criteria.

Pilot review: : Review and testing of the present guideline by clinicians to evaluate aspects of the guideline such as clarity, clinical applicability, flexibility, resource utilization, training needs, and cost of guideline implementation. Review of a consumer version of the present guideline by consumers and clinicians to evaluate its clarity, usefulness, flexibility, and accuracy.

Quasi-experimental study: : (Includes nonrandomized controlled trial or nonrandomized clinical trial) A design that does not use random assignment to create treatment and control groups but uses other methods to control validity threats so that changes can be inferred or attributed to the experimental treatment.

Scientific review: : An exhaustive literature search to define and critically evaluate the knowledge base for pain assessment and interventions.

## Pain Physiology

Anxiolysis:: Sedation or hypnosis used to reduce anxiety, agitation, or tension.

Neuropathic pain:: Pain that arises from a damaged nerve.

Nociception:: The process of pain transmission; usually relating to a receptive neuron for painful sensations.

Pain:: An unpleasant sensory and emotional experience associated with actual or potential tissue damage or described in terms of such damage.

Pain threshold level:: The level of intensity at which pain becomes appreciable or perceptible.

## Nonpharmacologic Management

Acupuncture:: The piercing of specific body sites with needles to produce pain relief.

Counterirritant:: An agent that is applied to produce irritation at one site so as to decrease perception of pain at the same or a distant site.

Cryoanalgesia:: The destruction of peripheral nerves by extreme cold to achieve prolonged pain relief.

Cryotherapy:: The therapeutic use of cold to reduce discomfort, limit progression of tissue edema, or break a cycle of muscle spasm.

Patient education:: Providing the patient with an explanation of perioperative procedures, expected postoperative sensations, and instruction to help decrease mobility-related discomfort.

Relaxation methods:: A variety of techniques to help decrease anxiety and muscle tension; these may include imagery, distraction, and progressive muscle relaxation.

Tactile strategies:: Strategies that provide comfort through the sense of touch, such as stroking or massage.

TENS (transcutaneous electrical nerve stimulation):: A method of producing electroanalgesia through electrodes applied to the skin.

## Pain Assessment

Conscious sedation:: "Light sedation" during which the patient retains airway reflexes and responses to verbal stimuli.

Oximetry:: Determination of the oxygen saturation of arterial blood, typically by means of an external probe applied around a finger or toe.

Paradoxical reaction:: A response (e.g., to a drug) that is the opposite of the usual response, such as agitation produced in a individual patient by a drug normally considered to be a sedative.

## Pharmacologic Management

EMLA (eutectic mixture of local anesthetic):: An ointment that contains local anesthetics so that topical application causes local anesthesia without the need for injection.

Epidural:: Situated within the spinal canal, on or outside the dura mater (tough membrane surrounding the spinal cord); synonyms are "extradural" and "peridural."

Equianalgesic:: Having equal pain killing effect; for example, morphine sulfate 10 mg intramuscular is generally used for opioid analgesic comparisons.

Interpleural:: Situated between the membrane surrounding the lungs and the membrane lining the thoracic cavity.

Intrathecal:: Within a sheath (e.g., cerebrospinal fluid that is contained within the dura mater).

Local nerve block:: Infiltration of a local anesthetic around a peripheral nerve so as to produce anesthesia in the area supplied by the nerve.

Mixed opioid agonist-antagonist:: A compound that has an affinity for two or more types of opioid receptors and blocks opioid effects on one receptor type while producing opioid effects on a second receptor type.

NSAID (nonsteroidal anti-inflammatory drug):: Aspirin-like drug that reduces pain and inflammation arising from injured tissue.

Opioid agonist: : Any morphine-like compound that produces bodily effects including pain relief, sedation, constipation, and respiratory depression.

Opioid partial agonist: : A compound that has an affinity for and stimulates physiological activity at the same cell receptors as opioid agonists but that produces only a partial (i.e., submaximal) bodily response.

PCA (patient controlled analgesia): : Self-administration of an analgesic by a patient instructed in doing so; usually refers to self-dosing with intravenous opioid (e.g., morphine) administered by means of a programmable pump.

Peridural: : Synonym for epidural and extradural.

Perineural: : Surrounding a nerve.

## References

- Cook, T.D. & Campbell, D.T. (1979). Quasi-experimentation: Design and analysis issues for field settings. Chicago: Rand McNally College Publishing Co.
- Field, M.D. & Lohr, K.N. (Eds.). (1990). Clinical practice guidelines: Directions for a new program. Committee to Advise the Public Health Service on Clinical Practice Guidelines, Institute of Medicine. Washington: National Academy Press.
- International Association for the Study of Pain. (1979). Pain terms: A list with definitions and notes on usage. Pain, 6, 249.