# Executive Summary

Clinical surveys continue to indicate that routine orders for intramuscular injections of opioid as needed fail to relieve pain in about half of postoperative patients. Recognition of the widespread inadequacy of pain management has prompted recent corrective efforts within multiple health care disciplines, including surgery, anesthesiology, and nursing, as well as pain management groups.

This Clinical Practice Guideline for Acute Pain Management: Operative or Medical Procedures and Trauma was commissioned by the Agency for Health Care Policy and Research (AHCPR). The guideline is designed to help clinicians, patients, and patients' families to understand the assessment and treatment of postoperative and other acute pain in both adults and children.

To develop the guideline, AHCPR convened an interdisciplinary panel of physicians, nurses, a pharmacist, a psychologist, a physical therapist, a patient/consumer, and an ethicist. The guideline development process included an extensive review of current needs, therapeutic practices and principles, and emerging technologies for postoperative pain control. All pertinent guidelines and standards were reviewed, opinions were obtained from external consultants, and testimony was received at an open forum held on November 20, 1990 in Washington, DC. An exhaustive literature search was conducted to define the knowledge base and critically evaluate the assumptions and common wisdom of the field. Although the review focused primarily on postoperative pain, literature on procedure-related and trauma pain was also considered. Drafts of the guideline were peer-reviewed and then tested in the field by intended users in various clinical sites.

The guideline has four major goals:

1. Reduce the incidence and severity of patients' acute postoperative or posttraumatic pain.
2. Educate patients about the need to communicate unrelieved pain so they can receive prompt evaluation and effective treatment.
3. Enhance patient comfort and satisfaction.
4. Contribute to fewer postoperative complications and, in some cases, shorter stays after surgical procedures.

Not all acute postoperative, procedural, or trauma-related pain can be eliminated, but several alternative approaches, when appropriately and attentively applied, prevent or relieve pain. The importance of effective pain management increases beyond patient satisfaction when additional benefits for the patient are realized, e.g., earlier mobilization, shortened hospital stay, and reduced costs.

This guideline addresses the care of patients with acute pain associated with operations, medical procedures, or trauma. All age groups are covered, from neonates to the elderly. It outlines the physiological basis of pain and summarizes clinical studies linking effective postoperative pain management with improved patient outcomes.

Because patients vary greatly in medical conditions and operations, responses to pain and interventions, and personal preferences, the guideline offers a flexible approach to management of acute pain that clinicians can adapt and use in daily practice.

The guideline emphasizes:

- A collaborative, interdisciplinary approach to pain control, including all members of the health care team and input from the patient and the patient's family, when appropriate;
- An individualized proactive pain control plan developed preoperatively by patients and practitioners (since pain is easier to prevent than to bring under control, once it has begun);
- Assessment and frequent reassessment of the patient's pain;
- Use of both drug and nondrug therapies to control and/or prevent pain;
- A formal, institutional approach to management of acute pain, with clear lines of responsibility.

The guideline includes strategies for overall pain control as well as site- specific pain control and addresses issues related to special groups such as children and the elderly. Additionally, it contains analgesic dosage tables for adults and children, sample pain assessment tools, examples of nondrug interventions, and pre- and postoperative pain management flow charts.

Guideline development is a dynamic process, and new therapies and technologies are always emerging. This is the first edition of the Clinical Practice Guideline for Acute Pain Management. Further editions will be prepared to reflect new research findings and experience with emerging technologies for pain assessment and relief.