# Acute Pain Management Guideline Panel

## Panels Members and Tenure on Panel

- Daniel B. Carr, MD
- Panel Co-Chair 1990 -
- Director, Division of Pain Management
- Department of Anesthesia
- Massachusetts General Hospital
- Ada K. Jacox, RN, PhD, FAAN
- Panel Co-Chair 1990 -
- Independence Foundation Chair in Health Policy
- School of Nursing
- The Johns Hopkins University
- C. Richard Chapman, PhD
- 1990 -
- Professor of Anesthesiology
- School of Medicine
- University of Washington
- Betty Ferrell, RN, PhD, FAAN
- 1991 -
- Research Scientist
- Nursing Research
- City of Hope Medical Center
- Howard L. Fields, MD, PhD
- 1990 - 1991
- Departments of Neurology and Physiology
- University of California,
- San Francisco
- George Heidrich III, RN, MA
- 1990 - 1991
- Instructor, Department of Neurology
- University of Wisconsin
- Medical School
- Nancy K. Hester, RN, PhD
- 1990 -
- Assistant Director, Center for Nursing Research,
- Associate Professor, School of Nursing
- Health Sciences Center
- University of Colorado
- C. Stratton Hill, Jr., MD
- 1990 -
- Professor of Medicine
- MD Anderson Cancer Hospital
- University of Texas
- Arthur G. Lipman, PharmD
- 1990 -
- Professor of Clinical Pharmacy
- College of Pharmacy
- University of Utah
- Charles L. McGarvey, MS
- 1990 -
- Chief, Physical Therapy Service
- Department of Rehabilitation Medicine
- National Institutes of Health
- Christine Miaskowski, RN, PhD
- 1990 -
- Associate Professor,
- Department of Physiological Nursing
- University of California,
- San Francisco
- David Stevenson Mulder, MD
- 1990 -
- Professor of Surgery
- McGill University
- Surgeon-in-Chief
- Montreal General Hospital
- Richard Payne, MD
- 1990 -
- Associate Professor of Neurology
- University of Cincinnati
- Medical Center
- Neil Schecter, MD
- 1990 - 1991
- Associate Professor of Pediatrics
- Head, Division of Developmental and Behavioral Pediatrics,
- University of Connecticut School of Medicine
- Co-Director, Children's Pain Service
- University of Connecticut Health Center
- Barbara S. Shapiro, MD
- 1991 -
- Associate Director
- Multidisciplinary Pain Management Program,
- Division of General Pediatrics, Children's Hospital of Philadelphia
- Robert S. Smith, PhL
- 1990 -
- Director, Institute for Medicine in Contemporary Society
- State University Medical Center at Stony Brook
- Carole V. Tsou, MD
- 1990 -
- Division of Family Medicine
- UCLA Center for Health Sciences
- Loretta Vecchiarelli
- 1990 -
- Rehabilitation Counselor and Burn Survivor
- Rehabilitation Hospital of Western
- New England

## Panel Staff

- Jane Ballantyne, MB, BS
- 1990 -
- Technology Assessment Group
- Harvard School of Public Health
- Donna Mahrenholz, RN, PhD
- 1990 -
- School of Nursing
- The Johns Hopkins University
- Janice Fitzgerald Ulmer, RN, PhD
- 1990 -
- School of Nursing
- The Johns Hopkins University

## Consultants

- Thomas C. Chalmers, MD
- 1990 -
- Technology Assessment Group
- Harvard School of Public Health
- Frederick Mosteller, PhD
- 1990 -
- Department of Health Policy and Management
- Harvard School of Public Health
- Barker Bausell, PhD
- 1991 -
- Center for Research
- School of Nursing
- University of Maryland