# Summary

Summary recommendations 1-5 and 7, below, should be implemented in every hospital where operations are performed on inpatients. The Acute Pain Management Guideline Panel recommends that any hospital in which abdominal or thoracic operations are routinely performed offer patients postoperative regional anesthetic, epidural or intrathecal opioids, PCA infusions, and other interventions requiring a similar level of expertise, under the supervision of an acute pain service as described in summary recommendation 6, below. For pain management to be effective, each hospital must designate who or which department will be responsible for all of the required activities.

There are a number of alternative approaches to preventing or relieving postoperative pain, many of which can give good results if attentively applied. The following elements, however, apply to most cases and might serve as a focus for assessing the results of these guidelines:

1. Promise patients attentive analgesic care. Patients should be informed before surgery, verbally and in printed format, that effective pain relief is an important part of their treatment, that talking about unrelieved pain is essential, and that health professionals will respond quickly to their reports of pain. It should be made clear to patients and families, however, that the total absence of any postoperative discomfort is normally not a realistic or even a desirable goal.
2. Chart and display assessment of pain and relief. A simple assessment of pain intensity and pain relief should be recorded on the bedside vital sign chart or a similar record that encourages easy, regular review by members of the health care team and is incorporated in the patient's permanent record. The intensity of pain should be assessed and documented at regular intervals (depending on the severity of pain) and with each new report of pain. The degree of pain relief should be determined after each pain management intervention, once a sufficient time has elapsed for the treatment to reach peak effect. A simple, valid measure of intensity and relief should be selected by each clinical unit. For children, age-appropriate measures should be used.
3. Define pain and relief levels to trigger a review. Each institution should identify pain intensity and pain relief levels that will elicit a review of the current pain therapy, documentation of the proposed modifications in treatment, and subsequent review of its efficacy. This process of treatment review and followup should include participation by physicians and nurses involved in the patient's care.
4. Survey patient satisfaction. At regular intervals defined by the clinical unit and quality assurance committee, each clinical unit should assess a randomly selected sample of patients who have had surgery within 72 hours. Patients should be asked their current pain intensity, the worst pain intensity in the past 24 hours, the degree of relief obtained from pain management interventions, satisfaction with relief, and their satisfaction with the staff's responsiveness.
5. Analgesic drug treatment should comply with several basic principles:
  - a. Non-opioid "peripherally acting" analgesics. Unless contraindicated, every patient should receive an around-the- clock postoperative regimen of an NSAID. For patients unable to take medications by mouth, it may be necessary to use the parenteral or rectal route.
  - b. Opioid analgesics. Analgesic orders should allow for the great variation in individual opioid requirements, including a regularly scheduled dose and "rescue" doses for instances in which the usual regimen is insufficient.
6. Specialized analgesic technologies, including systemic or intraspinal, continuous or intermittent opioid administration or patient controlled dosing, local anesthetic infusion, and inhalational analgesia (e.g., nitrous oxide) should be governed by policies and standard procedures that define the acceptable level of patient monitoring and appropriate roles and limits of practice for all groups of health care providers involved. The policy should include definitions of physician and nurse accountability, physician and nurse responsibility to the patient, and the role of pharmacy.
7. Nonpharmacological interventions: Cognitive and behaviorally based interventions include a number of methods to help patients understand more about their pain and to take an active part in its assessment and control. These interventions are intended to supplement, not replace, pharmacological interventions. Staff should give patients information about these interventions and support patients in using them.
8. Monitor the efficacy of pain treatment: Periodically review pain treatment procedures as defined in summary recommendations 1-4 above, using the institution's quality assurance procedures.