# Responsibility for Effective Pain Relief

Optimal application of pain control methods depends on cooperation between different members of the health care team throughout the patient's course of treatment. To ensure that this process occurs effectively, formal means must be developed and used within each institution to assess pain and to obtain patient feedback to gauge the adequacy of its control (American Pain Society, 1990, 1991 ; National Institutes of Health, 1987).

The institutional process of acute pain management begins with an affirmation that patients should have access to the best level of pain relief that may safely be provided. Each institution should develop the resources necessary to provide the best and most modern pain relief appropriate to its patients.

In any setting, the quality of pain control will be influenced by the availability of a pain management program and the training, expertise, and experience of its members.

In any setting, the quality of pain control will be influenced by the availability of a pain management program and the training, expertise, and experience of its members. There is wide variation among institutions in size, complexity, volume of surgical procedures, and differing patient populations; therefore, different pain management programs are suitable. In all cases, responsibility for this care should be assigned to those most knowledgeable, experienced, interested, and available to deal with patients' needs in a timely fashion.

Risks associated with sophisticated options for effective pain relief, such as epidural analgesia or PCA, are minimized by encouraging their application in an organized, methodical fashion with frequent followup and titration. It is logical to assign responsibility for effective pain relief under such circumstances to experts working in dedicated groups. The sense of security present in many hospitals where such dedicated groups are active should not seduce other providers into offering sophisticated pain relief options beyond the institutional resources to manage them vigilantly. Patient controlled or epidural analgesia, or even conventional analgesia given by injection, are all potentially lethal. Death can occur if dosages are not titrated, drug interactions not watched for, and patients not monitored for side effects like respiratory depression. In this sense, analgesics should be prescribed with no less care and expertise than other medications such as digitalis or insulin. In settings where pain management teams are not feasible (e.g., surgicenters, primary care clinics, or nursing homes), less sophisticated options may be appropriate, yet responsibility for effective pain control should still be assigned to designated, accountable individuals. Only if institutions recognize the importance of effective pain control and assign responsibility to interested individuals or groups can the quality of care in this area be at its best.

The key items to be considered when developing an institutional quality assurance program to monitor the provision of pain relief are:

- Patient comfort and satisfaction with pain management.
- The range and appropriateness of options available within a particular institution.
- How those options can best be applied.
- Minimizing side effects and complications related to pain control.

Implementation of this guideline requires more than quality assurance procedures: interdisciplinary, interprovider collaboration should occur. Three elements are essential for interdisciplinary collaboration: a common purpose, diverse professional skills and contributions, and effective coordinating and communicating processes. For nurses, physicians, and others treating acute pain, the common purpose is relief of patients' pain. The purpose should be explicit, and a commitment to this goal should be elicited from every provider who can influence the patient's pain. Each health professional's diverse and complementary skills and contributions should be recognized and used toward meeting the common goal of pain relief. Knowledgeable and talented providers with a common purpose may not achieve effective pain control without effective communication and coordination. The following elements will help ensure successful collaboration:

- Clarity among professionals about what they can and will contribute (such as, who will coordinate pain management -- primary nurse, and attending physician or specialized pain control team?; can consultants write prescriptions or orders?).
- Decisionmaking that reflects input from the patient and family (when appropriate), such as providing when feasible a menu of pain control choices that includes pharmacologic and nonpharmacologic means.
- Contingency planning, such as orders to avert or treat possible drug side effects like constipation, nausea, or urinary retention; a range of analgesic doses to deal with varying pain intensity; postdischarge followup of acute pain problems such as phantom pain; and clear coverage for off-shifts or weekends.
- Regular meetings (e.g., daily rounds) of all providers (as many, and as interdisciplinary as possible) at mutually convenient times to maximize communication and information sharing.

In addition to the above clinical communications, interpersonal issues of power, leadership, and conflict can hamper efforts to relieve pain. An ability to analyze these situations, as well as interpersonal competence in leadership and conflict resolution, are vital for building teams and keeping them focused on their shared purpose of relieving pain.