# Management of Postoperative and Procedural Pain in Infants, Children, and Adolescents

Much of the guideline thus far applies to both adults and children. The following section contains information specific to pain assessment and management in children. This section is not all-inclusive, and these recommendations should be used in conjunction with the entire guideline. This portion of the guideline, although based on a thorough review of the literature on procedure-induced and postoperative pain, is not a substitute for professional training and judgment. For further information, the clinician is referred to the bibliography and, when necessary, to experts for consultation.

## Background

Children commonly experience postoperative pain. The incidence of moderate to severe pain in children in any health care setting is influenced by factors such as the child's medical condition, type of procedure performed, and attitudes of health care professionals toward pain management. In three studies on postoperative pain in children, the prevalence of moderate to severe pain varied from about 40 to 60 percent (Hester, Foster, Kristensen, and Bergstrom, 1989 ; Johnston, Jeans, Abbott, Grey-Donald, and Edgar, 1988 ; Mather, and Mackie, 1983).

Many children do not receive any opioid analgesics after surgical procedures, even though painful postoperative courses are expected (Beyer, DeGood, Ashley, and Russell, 1983 ; Eland, and Anderson, 1977; Foster, and Hester, 1990a, 1990b ; Hester, Foster, Kristensen, and Bergstrom, 1989 ; Schechter, and Allen, 1986). Compared with adults undergoing similar procedures, less potent analgesic regimens usually are ordered for and given to children (Beyer, DeGood, Ashley, and Russell, 1983 ; Schechter, and Allen, 1986). When used, opioid doses and intervals of administration are often inadequate; when a physician's order includes a selection of one or more analgesics, the tendency is to choose the least potent drugs (Beyer, DeGood, Ashley, and Russell, 1983 ; Foster, and Hester, 1989, 1990a ; Mather, and Mackie, 1983). In general, although children are less able than adults to articulate their treatment and medication needs, both opioid and non-opioid analgesics are commonly prescribed on an "as-needed" basis (Beyer, DeGood, Ashley, and Russell, 1983 ; Bush, Holmbeck, and Cockrell, 1989). This type of prescription (a) requires the child or the family to describe the presence of pain and the need for analgesia and (b) focuses on the treatment of emerging pain rather than aggressive treatment to prevent pain.

Infants, even when premature, experience pain in response to aversive stimuli (Anand, 1990 ; Anand, and Aynsley-Green, 1988 ; Anand, Sippell, and Ansley-Green, 1987; Fitzgerald, Millard, and MacIntosh, 1988, 1989 ; Fitzgerald, Shaw, and MacIntosh, 1988). However, infants often do not before or after major medical procedures (Franck, 1987). Although the majority of ventilated infants receive postoperative opioid analgesia (but often in less than adequate doses), nonventilated infants often do not (Campbell, Reynolds, and Perkins, 1989 ; Purcell-Jones, Dormon, and Sumner, 1988 ; Schnurrer, Marvin, and Heimbach, 1985). A survey of the beliefs and practices of anesthesiologists in the United Kingdom revealed that, although the majority believed neonates experience pain, few provided opioid analgesics for postoperative pain (Purcell-Jones, Dormon, and Sumner, 1987). Discrepancies between beliefs and practices can occur for many reasons, but they have not been adequately explored.

Invasive and painful procedures are particularly distressing for children. Children often describe repeated invasive procedures as more distressing than any other aspect of illness or treatment (Eland, and Anderson, 1977 ; Fowler- Kerry, 1990 ; Jay, Ozolins, Elliott, and Caldwell, 1983 ; Weekes, and Savedra, 1988). Unlike adults, infants and young children may not understand the reason for procedures and may not participate actively in providing consent. Infants and young children also may not understand the time-limited nature of procedures. Although appropriate preparation and adequate analgesia for painful procedures are crucial for decreasing distress in children, these issues often are not addressed by health care providers, or they are approached haphazardly (Schechter, 1989).

## Assessment

Pain is determined by many factors, including the medical condition, developmental level, emotional and cognitive state, personal concerns, meaning of pain, family issues and attitudes, culture, and environment. Caring for the child in pain requires frequent assessment and reassessment of the presence, amount, quality, and location of pain. It also means preventing or reducing anticipated pain and, when prevention is not possible, promptly alleviating pain. Because emotional distress accentuates the experience of pain, exploration of and intervention for possible sources of distress are necessary. For infants and children, the provider should recognize the potential for pain and pursue the possibility that a child is in pain. A knowledge of children, including their developmental level and their behavior, is necessary to adequately assess pain and distress.

Pediatric pain assessment includes a pain history, a search for diagnoses such as infection that could be increasing or causing pain, evaluation of the pain severity and location, and observation of the child and his or her responses to the environment. The inclusion of parents or guardians and other important family members is essential to pain assessment. Strategies for assessment should be tailored to the developmental level and personality of the child and to the context. Children who are developmentally delayed or retarded, learning disabled, emotionally disturbed, or non-English speaking require special assessment. Culturally determined beliefs about pain and medical care also should be considered. Getting to know the individual child is important for assessment and management of pain: obtaining a pain history and involving the parents in the child's care can optimize this process.

For infants and children, the provider should recognize the potential for pain or suspect that a child is in pain.

The pain history (see appendix D), obtained prior to or at admission, focuses on the language the child uses to describe pain (e.g., hurt, owie, boo- boo), previous pain experiences and coping strategies, how and to whom the child communicates pain, and the child's and the family's preferences to assess and treat pain (Hester, and Barcus, 1986). The provider, child, and family can then decide together on their approach to pain assessment and treatment.

Routine assessment and documentation of pain are critical for effective pain control. The frequency of assessment is tailored to the severity of the pain. For example, after a major surgical procedure, assessment reasonably could occur at least every 2 hours on the day of surgery and the first postoperative day and at least every 4 hours on subsequent days. More frequent assessment is necessary if the pain is poorly controlled despite treatment. Pain intensity and its response to analgesics should be recorded on the bedside chart just as vital signs are recorded for easy review by health care providers. Structured documentation on a bedside flow sheet may increase the frequency of assessment and provision of analgesia (Stevens, 1990). Assessment methods should be easy to administer or perform, and documentation forms should be readily accessible to health care providers for use in recording pain. If the child is old enough to participate in assessment, his or her ease in response is important for accurate measurement. Young children may not understand the relationship between pain assessment and pain relief; therefore, they may not respond to questions if they are anxious or in severe pain.

### Methods for assessing pain

No one method to assess pain offers an error-free measure of the pediatric pain experience. Therefore, the use of more than one method of assessment may be helpful. Assessment tools should be appropriate for the child's age and cognitive development and for the context. A variety of assessment tools are available for all age groups; selection of appropriate tools depends on the psychometric adequacy of the tool as determined through estimates of reliability, validity, generalizability, and sensitivity. Several psychometrically sound and developmentally appropriate tools are available to assess pain for documentation on a bedside flow sheet. Representative tools are described in appendix D.

As with adults, a self-report tool provides the most reliable and valid estimates of pain intensity, quality, and location. Self-reports can be used for developmentally normal children over the age of 4 (McGrath, 1990). Self- report tools for children over the age of 4 include the Oucher (Beyer, 1984), the Poker Chip Tool (Hester, 1979 ; Hester, Foster, and Kristensen, 1990), and a faces scale (McGrath, deVeber, and Hearn, 1985). Children over the age of 7 or 8 who understand the concept of order and number can use a numerical rating scale (McGrath, and Unruh, 1987), a horizontal word-graphic rating scale (Savedra, Tesler, Holzemer, and Ward, 1989), or a visual analog scale (Aradine, Beyer, and Tompkins, 1988). In a recent study, 958 well children and adolescents and 175 hospitalized children and adolescents rated the visual analog scale as the least preferred of five horizontal pain scales (Tesler, Savedra, Holzemer, Wilkie, Ward, and Paul, 1991). Reliability and validity for postoperative pain have been established for the Oucher, the Poker Chip Tool, and the horizontal word-graphic rating scale.

Children in pain or otherwise stressed may regress. For example, a child who before surgery uses a numerical scale appropriately may require a simpler scale after surgery. Similarly, children who are developmentally delayed or learning disabled may need assessment tools developed for younger children. If the child is unable or unwilling to respond, ratings can be obtained from the parents or health care providers. However, such ratings often underestimate moderate to severe pain and may overestimate lesser pain (Hester, Foster, Kristensen, and Bergstrom, 1989). To increase accuracy and consistency, ratings from parents and health care providers are obtained using the same tool as the child uses.

Observation of behavior is the primary assessment method for the nonverbal child and may be an adjunct to assessment for the verbal child. Such observations focus on vocalizations, verbalizations, facial expressions, motor responses, and activity. To obtain meaningful observations, the health care professional watches for and documents behaviors associated with distress. Several aspects of behavior should be observed. For example, a child may move easily in bed, guard the surgical site when moving, or be completely immobilized and resist movement.

Various scales based on behavioral observations have been designed for clinical use in infants and preverbal children (Barrier, Attia, Mayer, Amiel- Tison, and Shnider, 1989 ; Gauvain-Piquard, Rodary, Rezvani, and Lemerle, 1987 ; McGrath, Johnson, Goodman, Schillinger, Dunn, and Chapman, 1985). Although reliability and validity have not been well established, these scales offer a guide for observations of postoperative pain.

Use of behavioral observation to guide analgesia requires attention to the context of the child's behavior. For example, children cry not just in response to pain but also in response to fear, loneliness, and over- or understimulation. Thus, additional assessment is necessary when the source of a behavior is not evident, so that all sources of distress can receive appropriate intervention. Sleeping, watching television, or joking may be misinterpreted as indicators of no pain while the child may, in fact, be attempting to control pain. Behavioral responses may be absent or attenuated in circumstances where vocalization or movement increase pain or where intubation, use of paralyzing agents or sedatives, extreme illness, weakness, or depression impede vocalizations and movement. If care providers are unsure whether a behavior indicates pain, and if there is reason to suspect pain, an analgesic trial can be diagnostic as well as therapeutic.

Unstructured observations of how a child looks and acts may provide additional information about the presence and amount of pain. Documenting observations over time may reveal specific changes in behavior that serve as important pain indicators. For example, a child may be alert and talkative and then appear sullen and withdrawn. Such a change warrants further investigation since it may indicate the onset of or an increase in pain (Hester, and Foster, 1990).

Scales for assessing procedure-related pain have been developed. Assessment of facial expressions and the quality of crying have been used with infants [e.g., Neonatal Facial Coding System (Grunau, and Craig, 1987)]. The Procedure Behavior Rating Scale (Katz, Kellerman, and Siegel, 1980) and the Procedure Behavior Checklist (LeBaron, and Zeltzer, 1984) have been used with children. These tools are not applicable for routine postoperative use.

Physiologic indicators of pain and distress include heart rate, respiratory rate, blood pressure, and perspiration. However, these indicators are not specific for pain, and they vary among individual patients in pain. Therefore, the interpretation of physiological indicators should be done in the context of the clinical condition and in conjunction with other assessment methods.

## Management

Pain is managed by the child, his or her parent(s), nurses, physicians, and other health care providers. Effective interaction is key to effective pain management. Although preferences of the child and the family deserve respect and careful consideration, the primary obligation of the health care provider is to ensure safe and competent care.

Children attempt to prevent or alleviate pain whether or not health care providers do so. When in pain, a child often prefers the use of medication and the presence of a parent (Adams, 1990 ; Hester, 1989 ; Savedra, Gibbons, Tesler, Ward, and Wegner, 1982). However, children may not be in control of these strategies. Specific methods initiated by children that may be helpful include: holding someone's hand, a stuffed toy, or favorite blanket; asking questions; using distraction; sleeping and resting; relaxing or using imagery; changing positions; and engaging in humor. Seemingly simple interventions such as holding someone's hand can have powerful effects. Facilitation of the child's usual strategies for decreasing pain is important.

Although preferences of the child and the family deserve respect and careful consideration, the primary obligation of the health care provider is to ensure safe and competent care.

### Management of pain related to procedures in hospitalized children

Diagnostic and therapeutic procedures are often associated with pain. A structured approach to pain management takes into consideration the type of procedure, anticipated range of pain, and individual factors such as age and condition.

Nonpainful procedures (e.g., computed tomographic scanning, magnetic resonance imaging, cast changes, and ultrasonic examination) often require a child to lie still. Preparatory education about the sensations and surroundings may decrease the child's distress and facilitate the procedure (Johnson, Kirchhoff, and Endress, 1975). Nondrug approaches such as distraction and imagery may benefit the older child (Zeltzer, Altman, Cohen, LeBaron, Maunuksela, and Schechter, 1990). Sedation is appropriate in these situations, particularly if the child is under 6 years of age. Sedatives include oral chloral hydrate or pentobarbital. Pharmacologic sedation may result in the loss of the child's protective reflexes; therefore, children should be closely monitored even during "conscious sedation."

Painful procedures require a management plan that may include both drug and nondrug approaches. When planning the management of procedure- related pain and anxiety, a series of questions should be asked: 1) Why is the procedure being performed? 2) What is the expected intensity of pain? 3) What is the expected duration of pain? 4) What is the expected intensity of anxiety? 5) What is the expected duration of anxiety? 6) How often will the procedure be repeated? 7) How do the parents think the child will react? and 8) What are the child's and family's perceptions regarding the procedure? The following are general management principles for procedures:

- Treat anticipated procedure-related pain prophylactically.
- Ensure the competency of the person performing the procedure and the timeliness of the procedure (Zeltzer, Altman, Cohen, LeBaron, Maunuksela, and Schechter, 1990). Delays can escalate pain and anxiety. Children report that procedures are easier to tolerate if they know and trust the people doing them.
- Provide adequate and unhurried preparation of the child and family. Parental prediction of the child's response is highly correlated with the actual degree of distress (Fradet, McGrath, Kay, Adams, and Luke, 1990 ; Schechter, Bernstein, Beck, Hart, and Sherzer, 1991).
- Be attentive to environmental stimuli and the manner in which the child is handled. A room other than the child's room should be used whenever possible. Environmental factors, such as cold or crowded rooms or "beepers" on machines, can escalate distress (Fowler- Kerry, 1990 ; Hester, 1989).
- Allow parents to be with the child during the procedure. The presence of a parent may be a source of great comfort for the child (Bauchner, Waring, and Vinci, 1991 ; Shaw, and Routh, 1982). The parent's knowledge of the child can be invaluable. Parents should be educated, since they do not automatically know what to do, where to be, and what to say to help their child through the procedure.
- Tailor treatment options, both drug and nondrug, to the child's and the family's needs and preferences, to the procedure, and to the context. A child who undergoes a procedure as part of the treatment for a chronic or life-threatening disease has different needs from the child who has an occasional procedure as part of general well child care or for treatment of an acute but self-limited illness.
- If at all possible, administer pharmacologic agents by a route that is not painful (e.g., oral, transmucosal, or intravenous). If one or two doses of a parenteral agent are necessary and the child does not have intravenous access, a single injection may be preferable to multiple attempts at insertion of an intravenous catheter.
- Dovetail pharmacologic and nonpharmacologic options to complement one another.
- For repeated procedures, maximize treatment for the pain and anxiety of the first procedure to minimize anxiety before future procedures.
- Provide monitoring and resuscitative equipment if drugs are used for sedation. Facilities, equipment, and personnel to manage emergencies (e.g., vomiting, and anaphylaxis) should be immediately available.
- Manage preexisting pain optimally before beginning the procedure.
- After the procedure, review with the child and family their experiences and perceptions about the effectiveness of pain management strategies.

## Pharmacologic Strategies for Procedural Pain

The needs of the individual child and the type of procedure to be performed shape the pharmacologic approach. As with assessment, the practitioner's expertise and experience with children are key to successful therapy. A pain-relieving agent, such as an opioid (see appendix C for starting doses) or a local anesthetic, is needed to reduce the pain. Anxiolytics and sedatives are used specifically to reduce anxiety before and during the procedure; if used alone, they may blunt the behavioral response without relieving the pain. When anxiety is present, pharmacologic anxiolysis can complement analgesia to decrease overall distress. The use of systemic analgesics and sedatives must be approached differently in the infant under 6 months of age (see section on Managing Postoperative Pain in Neonates, and Infants).

Agents that have a broad range of applicability include:

- Local anesthetics: These agents may be administered by local infiltration or topically. For topical use, a eutectic mixture of local anesthetics (EMLA) (Maunuksela, and Korpela, 1986) is promising but not yet available in the United States.
- Opioids: These drugs can be given via the intravenous, oral, or transmucosal route. The intravenous route has the advantage of rapid effect and ease of titration. Intravenous opioids can be given in increments (e.g., morphine at 0.03-0.05 mg/kg every 5 minutes) and titrated to analgesic effect. Oral opioids can be used when close and rapid titration to effect is not required.
- Benzodiazepines: These agents can be given either orally or intravenously. Like opioids, intravenous benzodiazepines are given in increments and titrated to sedative effect (Zeltzer, Altman, Cohen, LeBaron, Maunuksela, and Schechter, 1990). Unlike diazepam, midazolam does not cause pain and local sclerosis when given intravenously (Zeltzer, Altman, Cohen, LeBaron, Maunuksela, and Schechter, 1990). Benzodiazepines provide sedation, not analgesia, and hence they often are used with opioids for painful procedures. If the combination of opioid plus benzodiazepine is used, the risk of respiratory depression is increased.
- Barbiturates: These drugs provide excellent sedation. They have no analgesic effects and are used with analgesics for painful procedures. For most patients, the sedation persists for many hours after the procedure is completed (Zeltzer, Jay, and Fisher, 1989); rarely, some patients may have paradoxical reactions. As with benzodiazepines, close observation for respiratory depression is essential, particularly when the intravenous route is employed or if an opioid is coadministered.

NOTE: Exercise caution when using the mixture of meperidine (Demerol), promethazine (Phenergan), and chlorpromazine (Thorazine), also known as DPT. DPT -- given intramuscularly -- has commonly been used for painful procedures. The efficacy of this mixture is poor when compared with alternative approaches, and it has been associated with a high frequency of adverse effects (Nahata, Clotz, and Krogg, 1985). It is not recommended for general use and should be used only in execptional circumstances.

Agents such as nitrous oxide and ketamine can be used if trained personnel and appropriate monitoring procedures are available (Zeltzer, Jay, and Fisher, 1989). General anesthesia is appropriate in certain situations (Zeltzer, Altman, Cohen, LeBaron, Maunuksela, and Schechter, 1990).

### Monitoring conscious sedation for procedural pain

Skilled supervision is necessary whenever systemic pharmacologic agents are used for conscious sedation (i.e., the patient maintains a response to verbal, and physical stimuli). A health care provider not involved in performing the procedure or holding the child should monitor for conscious sedation including frequent assessment of heart rate, respiratory rate and effort, blood pressure, and level of consciousness. Continuous pulse oximetry to measure arterial oxygen saturation is strongly encouraged. Immediate accessibility of resuscitative drugs and equipment and the presence of at least one health professional trained in advanced life support are necessary. After completion of the procedure, monitoring should continue until the child is fully awake and has resumed the former level of function.

Deep sedation (i.e., the patient is not responsive to verbal or physical stimuli) is equivalent to general anesthesia and should be performed only under controlled circumstances by a professional trained in its use and skilled in pediatric airway management and pediatric basic life support. Reference to specific published guidelines is recommended (American Academy of Pediatrics, 1985 ; American Academy of Pediatrics, in press). To quote from the latter guideline, "The caveat that loss of consciousness should be unlikely is a particularly important aspect of the definition of conscious sedation, and the drugs and techniques used should carry a margin of safety wide enough to render unintended loss of consciousness highly unlikely. Since the patient who receives conscious sedation may progress into a state of deep sedation and obtundation, the practitioner should be prepared to increase the level of vigilance corresponding to that necessary for deep sedation."

Hospitalized children undergo procedures that include lumbar punctures, chest tube insertions, bone marrow aspirates and biopsies, cardiac catheterization, circumcisions, and burn dressing changes. General principles for the management of procedural pain and distress can be applied to all painful procedures:

- Most hospitalized children undergo minor invasive procedures, such as heelsticks and fingersticks, injections, venipunctures, and insertion of intravenous catheters. Such procedures, even though categorized as "minor," can be a major source of distress for sick or hospitalized children. The hospitalized child benefits from predictability as to time and frequency and "clustering" of procedures, with an identified block of time when no procedures are to be performed, barring emergencies. Intramuscular and subcutaneous routes should be avoided unless necessary for proper administration (e.g., immunizations).
- Nondrug strategies are effective for pain and anxiety associated with minor procedures. Providing emotional support, eliciting concerns, and providing information and age-appropriate choices are crucial. Infants can benefit from sensorimotor interventions (i.e., using a pacifier, and using verbal or tactile strategies) (Campos, 1989 ; Field, and Goldson, 1984 ; Triplett, and Arneson, 1979). A variety of strategies have been studied in older children. The child and family can be prepared in several ways, such as provision of preparatory sensation information (Siegel, and Peterson, 1980, 1981); empathetic preparation (Fernald, and Corry, 1981); and a multimodality approach using stories, art, and play (Fassler, 1985). Other potentially effective cognitive-behavioral strategies include distraction techniques such as music (Fowler-Kerry, and Lander, 1987 ; Ryan, 1989); coping skills (Siegel, and Peterson, 1980, 1981); hypnosis (Andolsek, and Novik, 1980 ; Olness, 1981 ; Zeltzer, and LeBaron, 1982); play therapy (Ellerton, Caty, and Ritchie, 1985); and thought-stopping (Ross, 1984). Physical agents include TENS therapy (Eland, 1989) and counterirritants such as ice (Zeltzer, Altman, Cohen, LeBaron, Maunuksela, and Schechter, 1990). One or more nonpharmacologic intervention in addition to preparation can be chosen by the health care team, family, and child. Choice should be based on the child's preference, personality, and coping style.

For lumbar punctures, local anesthetics are used for all age groups, although efficacy in infants is controversial. Systemic drugs that alter mental status cannot be used in acute medical illnesses, such as meningitis, where observation of the level of consciousness is crucial to treatment. In situations where such monitoring is not necessary, younger children and many older ones benefit from a benzodiazepine. Supplementation with opioids is helpful for some cases, especially when difficulty in performing the procedure is anticipated. Children over 5 years of age who have learned and can effectively use cognitive and behavioral coping skills may prefer not to use sedatives or opioids (Zeltzer, Altman, Cohen, LeBaron, Maunuksela, and Schechter, 1990).

Management strategies for bone marrow aspirations and biopsies include use of either general anesthesia or conscious sedation using benzodiazepines and opioids, along with local anesthesia. Adequate time is necessary for the local anesthetic agent to have full effect.

Nonpharmacologic methods with demonstrated efficacy for lumbar punctures and bone marrow aspirates and biopsies include hypnosis (Zeltzer, and LeBaron, 1982); thought-stopping (Ross, 1984); and a multidimensional psychological intervention that includes a breathing exercise, reinforcement, imagery, behavioral rehearsal, and filmed modeling (Jay, Elliott, Ozolins, Olson, and Pruitt, 1985). Additionally, the strategies described for minor invasive procedures can be used for lumbar punctures and bone marrow aspirates and biopsies.

The management of pain associated with circumcision is controversial. Circumcision often has a religious context, and the religious beliefs of the family should be respected. Pain associated with circumcision can be managed with a penile block (Maxwell, Yaster, Wetzel, and Niebyl, 1987). However, recent evidence suggests that topical anesthesia may be a safe and effective option (Andersen, 1989 ; Tree-Trakarn, Pirayavaraporn, and Lertakyamanee, 1987).

## Pain Related to Burn Dressing Changes

Burn dressing changes in the child with burns severe enough to require hospitalization are approached in a multidisciplinary fashion, using drug and nondrug strategies. Pain and anxiety coexist in these situations and must be assessed and managed concurrently using opioids and benzodiazepines, respectively. Depending on the child and the level of anxiety, an opioid may be administered alone or used with a benzodiazepine. Since undertreatment of the pain can escalate anxiety, optimal pain control is necessary. Dressing changes occur repeatedly, and tolerance to opioids and benzodiazepines can develop, necessitating higher doses. For efficacy, doses should be increased as needed and titrated according to the response obtained during the previous procedure. The child also may have ongoing pain from the burns in addition to the pain and anxiety of the burn dressing changes. If the ongoing pain is not treated, the child's anxiety during the dressing changes may make it difficult to manage, even with significant doses of opioids and sedatives. Initial regimens for pain management may include a continuous infusion or around- the-clock intermittent doses of an opioid and additional bolus doses of an opioid and a benzodiazepine before the burn dressing changes. For extensive debridement procedures, conscious sedation may not be adequate; general anesthesia may be required.

A variety of nonpharmacologic approaches are effective adjuvants. These include hypnosis (Bernstein, 1963); a multimodal approach involving distraction, relaxation, imagery, and positive reinforcement (Elliott and Olson, 1983); and cartoon viewing with positive reinforcement (Kelley, Jarvie, Middlebrook, McNeer, and Drabman, 1984). Children as young as 18 months do better during burn dressing changes if their participation and control are maximized (Kavanagh, 1983a, 1983b). For example, a child can help to remove his or her own dressings and call for a "time-out" if necessary. Dressing changes are performed in a treatment room or similar place, so that the child can consider his or her room as a safe place. The time and environment for the dressing change should be predictable to the child. The situation causing the burns may be one that produces emotional distress for the child (e.g., burns sustained as a result of the child playing with fire or disobeying rules), and the developing body image of the child may be threatened by the burns. Psychiatric and psychologic intervention should be provided when necessary. Discharge planning initiated soon after admission can help relieve anxiety and increase compliance with the therapeutic regimen, particularly for children with burns on more than 30 percent of the body surface area (Quay, and Alexander, 1983).

## Management of Pain Associated With Surgical Procedures

Management of surgical pain involves three phases: preoperative, intraoperative, and postoperative.

### Preoperative management

Individual or group psychological preparation with or without home preparation (Ferguson, 1979 ; McGrath, 1979 ; Visintainer, and Wolfer, 1975 ; Wolfer, and Visintainer, 1979) may decrease pain, anxiety, and distress before and after the operation. Parental presence during the induction of anesthesia decreases postoperative pain and reduces adverse psychological sequelae (Hannallah, and Rosales, 1983 ; Johnston, Bevan, Haig, Kirnon, and Tousignant, 1988 ; Schofield, and White, 1989). Preoperative medication should be given painlessly. For example, a child with intravenous access can receive medication by that route; alternative routes for the child without intravenous access include oral, rectal, and transmucosal administration.

### Intraoperative management

Adequate analgesia for preterm and fullterm infants significantly reduces surgical stress and postoperative morbidity (Anand, Brown, Causon, Christofides, Bloom, and Aynsley-Green, 1985 ; Anand, and Hickey, 1987). This finding directly challenges the previous practice of providing minimal intraoperative anesthesia for infants based on concerns about the respiratory and hemodynamic side effects of opioids. High dose opioid anesthesia appears to be well tolerated, even in critically ill infants, provided it is used in a carefully monitored setting by skilled anesthesiologists (Collins, Koren, Crean, Klein, Roy, and MacLeod, 1985 ; Yaster, 1987).

Other intraoperative techniques that may help to reduce, delay, or prevent postoperative pain include epidural blockade with opioids and/or local anesthetics and local anesthetic infiltrated into the wound or applied to block a peripheral nerve. These approaches should be limited to personnel qualified in these anesthetic techniques. Children who receive intraoperative epidural opioids require careful monitoring after the procedure; this method should be used only in settings where such monitoring is available.

### Postoperative management

Drug therapies are the most important aspect of pain management. Nondrug techniques to reduce postoperative pain are useful adjuncts; the approaches are similar to those described for procedural pain: relaxation, distraction, the presence of a parent or a special toy or blanket, and cognitive preparation for anticipated events (Hester, 1989). Physical methods, such as positioning with blanket rolls for support and the use of heat or ice, also can be helpful. Pacifiers, swaddling, and a calming environment may be helpful for infants (Campos, 1989 ; Field, and Goldson, 1984).

Drug therapy for postoperative pain depends on the child's age, medical condition, type of surgery, and expected postoperative course. Pain after minor surgery, such as herniorrhaphy or tonsillectomy, usually can be managed with acetaminophen with or without codeine when the oral route is available. Often children are sent home on the day of surgery after such procedures; thus, parental instruction in pain control is important (Gedaly- Duff, and Ziebarth, 1991).

For major surgery, such as abdominal, thoracic, urologic, or orthopedic procedures, parenteral opioids are the mainstay of pain management. These drugs can be administered systemically or spinally, depending on individual needs. NSAIDs are useful in certain situations. Intravenous administration of NSAIDs is currently being studied in children; these and other agents may be used more widely in the future.

Some health care professionals are concerned about the potential for psychological dependence and addiction when using opioids for pain control in children. In adults, the risk of addiction after use of opioids for pain relief is small. Although studies of the risks in children are lacking, no known aspect of childhood development or physiology increases the risk of physiologic or psychologic vulnerability to chemical dependence.

Several issues are pertinent to opioid administration:

- Route: In the immediate postoperative period, systemic opioids are delivered by either the intravenous or epidural routes. Intramuscular injections are painful and frightening to children; many children would rather have pain than a "shot" (Eland, and Anderson, 1977). Since an intravenous catheter is required for hydration after major surgery, this route is always available. After the child is able to take medication by mouth, an oral opioid can be given with a non-opioid analgesic.
- Schedule: Intermittent boluses of opioids can be provided on an around-the-clock basis, using a dose of about 0.1 mg/kg of morphine or its analgesic equivalent. Dose intervals are the same as those recommended for adults. Continuous infusion of morphine (0.02-0.04 mg/kg/hr) for children over 6 months of age has been well studied (Bray, 1983 ; Hendrickson, Myre, Johnson, Matlak, Black, and Sullivan, 1990 ; Lynn, Opheim, and Tyler, 1984). Continuous infusion avoids the extreme variations that may occur with intermittent intravenous doses. "Rescue" doses for breakthrough or poorly controlled pain can be offered at regular intervals to patients receiving a continuous infusion. Because of wide variability in the opioid dose needed for adequate analgesia, no matter which route and schedule of administration is employed, pain and side effects (particularly respiratory depression) should be reassessed at frequent intervals and the dose and interval adjusted for the best pain relief.
- Agent: As in adults, morphine is the standard. Fentanyl may be preferable when cardiovascular stability is an issue and patients are closely monitored and/or intubated. Meperidine should be used only in exceptional circumstances. (See related discussion on pages 18 and 19.)
- Patient controlled analgesia: PCA provides safe and effective analgesia in children as young as 7 years of age (Berde, Lehn, Yee, Sethna, and Russo, 1991). This approach is appropriate for older children and adolescents, since it offers an element of developmentally appropriate control. The addition of a basal infusion may provide better analgesia without increasing the total dose of opioid (Berde, Lehn, Yee, Sethna, and Russo, 1991). Children and young adolescents may benefit from reminders to "push the button for pain" in the immediate postoperative period. Regular assessment and reassessment of pain and side effects, with adjustment of the PCA parameters as indicated, is necessary with PCA. Education of the patient and the family are key to the success of this approach. PCA must be supervised by professionals trained in its use.
- Side effects: The pharmacologic approach to managing side effects in children is similar to that in adults. However, young verbal children may have difficulty communicating subjective symptoms, like pruritus, nausea, and dysphoria; the preverbal child may show only generalized discomfort. Assessment of side effects occurs with assessment of pain relief. If an infant or preverbal child becomes increasingly restless or irritable despite an increased opioid dose, treatment of presumed side effects or a change to an alternative opioid can be considered.
- Monitoring: Regular assessment of vital signs and level of consciousness is necessary when parenteral opioids are used for managing postoperative pain. Because of wide inter- and intraindividual variations in the response to opioids, an occasional child will have an adverse reaction despite even the most careful titration of doses and intervals. The use of cardiorespiratory monitors is controversial, and professional judgment is required. In any case, machines cannot substitute for skilled and frequent assessment and observation by the health care provider.

## Regional Analgesia

Regional analgesia is now widely used for infants and children and may be particularly applicable for young infants as well. Hemodynamic and respiratory effects of major regional analgesia in infants appear minimal (Meignier, Souron, and LeNeel, 1983). The proper use of infusions or intermittent doses of epidural opioids and/or local anesthetics requires expertise and close monitoring, at least equal to that needed for infants receiving systemic opioids. An acute or postoperative pain service is usually necessary to provide the expertise and vigilance required.

Continuous epidural analgesia is effective for thoracic, abdominal, urologic, and orthopedic procedures (Hendrickson, Myre, Johnson, Matlak, Black, and Sullivan, 1990). Epidural infusions can be administered caudally (especially in children under 6 months of age) or via lumbar or thoracic epidural catheters in older children. Solutions infused into the epidural space are similar to but often more dilute than those applied in adults. Other regional techniques available to children include interpleural continuous infusions, brachial plexus infusions, lumbar sympathetic catheter infusions, and peripheral nerve blockade such as penile blocks.

## Managing Postoperative Pain in Neonates and Infants

Young infants, especially premature infants or those who have neurologic abnormalities or pulmonary disease, are susceptible to apnea and respiratory depression when systemic opioids are used (Way, Costley, and Way, 1965 ; Purcell-Jones, Dormon, and Sumner, 1987). Metabolism is altered so that the elimination half-life is prolonged, and the blood- brain barrier is more permeable (Collins, Koren, Crean, Klein, Roy, and MacLeod, 1985 ; Koehntop, Rodman, Brundage, Hegland, and Buckley, 1986 ; Koren, Butt, Chinyanga, Soldin, and Pape, 1985 ; Lynn, and Slattery, 1987). Thus, the adequate management of pain in this age group requires special consideration and expertise.

Clearly, neonates and infants experience pain, and adequate analgesia after surgery is necessary for both physiologic and ethical reasons. Institutions in which major surgery on neonates and infants is performed should provide training for personnel in the effective and safe administration of analgesia for children in this age group, as well as the technologic capability to provide appropriate monitoring. Several aspects of care should be noted.

Age. Some evidence suggests that the clearance of opioids increases rapidly over the first few weeks of life, and approaches adult rates by 1 to 2 months of age (Hertzka, Gauntlett, Fisher, and Spellman, 1989 ; Koren, Butt, Chinyanga, Soldin, and Pape, 1985 ; Lynn, and Slattery, 1987). Because the available data are based on small numbers of infants, most practitioners reduce the initial dose and use intensive monitoring for infants up to about 6 months of age; this age is arbitrary and based on a cautious interpretation of the literature. It is reasonable to continue intensive monitoring up to about 1 year of age, as extreme sedation and decreased effort of respiration may be more difficult to assess in this age group than in older children.

### Dosing and schedules

Although further investigation is necessary, apnea and respiratory depression appear to be dose related (Koren, Butt, Chinyanga, Soldin, and Pape, 1985). For nonventilated infants under 6 months of age, the initial opioid dose, calculated in milligrams per kilogram, should be about one-fourth to one-third of the dose recommended for older infants and children. For example, morphine could be used at a dose of 0.03 mg/kg instead of the traditional 0.1 mg/kg. Careful assessment is necessary after any dose, so that the optimal dose and interval of administration can be determined from clinical parameters (e.g., when pain breaks through, and whether the infant appears comfortable after the dose). Many infants have inadequate pain relief after the initial small dose and require upward titration, sometimes to doses used for older children. Continuous infusions can be used, but a reduced dose is again necessary.

Clearly, neonates and infants experience pain, and adequate analgesia after surgery is necessary for both physiologic and ethical reasons.

### Regional analgesia

Regional analgesia for neonates and young infants is as previously described for older infants and children.

### Monitoring

Close monitoring of heart and respiratory rates, respiratory effort, blood pressure, and responsiveness to stimuli is mandatory. Frequent or continuous assessment of arterial oxygen saturation using pulse oximetry is a valuable adjunct to close clinical observation. Serum levels of opioids may increase many hours after a one-time intramuscular or subcutaneous dose, presumably due to late release from tissue stores. Thus, monitoring is continued for 24 hours after an opioid dose (Koehntop, Rodman, Brundage, Hegland, and Buckley, 1986).

### Non-opioid analgesics

These analgesics (e.g., acetaminophen) can be safely administered to neonates and infants without concern for hepatotoxicity when given for short courses at the recommended doses (Berde, 1989, 1991). Acetaminophen can be given rectally or orally to augment analgesia.

## Responsibility for Effective Pain Relief in Children

A formal and structured institutional review of pain management is as necessary for children as for adults. It begins with affirming the rights of all children in any institution to receive the best level of pain relief that can be provided safely. The available methods of pain management should be appropriate for the medical conditions of the children and the surgical procedures that are performed. Recommendations in this guideline (see Responsibility for Effective Pain Relief, page 71) apply to children as well as adults. Patient and family feedback is necessary to ascertain and ensure the adequacy of pain management in children of all ages.

An environment centered on the child is necessary for adequate communication and assessment and to decrease the emotional distress of hospitalization. In addition to a staff experienced in caring for children, a child-centered environment lets parents participate in child care and provides adequate toys and age-appropriate activities.

## Critical Questions Regarding the Adequacy of Pain Management Strategies

Knowledge of children -- developmentally, behaviorally, and physiologically -- is necessary for optimal assessment and treatment. Children are likely to talk less about pain than adults. Thus, the burden of vigilance for pain rests with the health care provider. The following questions focus on decision points of pain management. These questions serve as a guide for the health care provider to optimize pain management. Some children, however, will present with pain that is difficult to manage. In these situations, consultation is recommended.

Children are likely to talk less about pain than adults. Thus, the burden of vigilance for pain rests with the health care provider.

Critical questions to consider before and during pharmacologic management include:

- Have the child and parent(s) been asked about their previous experiences with pain and their preferences for use of analgesics?
- Is the child being adequately assessed at appropriate intervals?
- Are analgesics ordered for prevention and relief of pain?
- Is the analgesic strong enough for the pain expected or the pain being experienced?
- Is the timing of drug administration appropriate for the pain expected or experienced?
- Is the route of administration appropriate (preferably oral or intravenous) for the child?
- Is the child adequately monitored for the occurrence of side effects?
- Are side effects appropriately managed?
- Has the analgesic regimen provided adequate comfort and satisfaction from the child's or parents' perspective?

Parallel questions regarding nonpharmacologic strategies include:

- Have the child and parent(s) been asked about their experience with and preferences for a given strategy?
- Is the strategy appropriate for the child's developmental level, condition, and type of pain?
- Is the timing of the strategy sufficient to optimize its effects?
- Is the strategy adequately effective in preventing or alleviating the child's pain?
- Are the child and parent(s) satisfied with the strategy for prevention or relief of pain?
- Are the treatable sources of emotional distress for the child being addressed?