# Site-Specific Pain Control

Even for a single operation, there may be great variability in the approach to postoperative pain management based on patient factors such as age, weight, ability to understand and cooperate with plans for care, coexisting medical and psychological problems, and idiosyncratic sensitivity to analgesics; intraoperative course, such as size and location of incisions or drain placement or anesthetic management; and institutional resources available for specialized treatment and monitoring in the particular setting.

Despite these variable factors, the clinician can still outline certain pain management options to present to an adult patient whose management is otherwise uncomplicated. Many aspects of pain control are shared between operations on different parts of the body. For practical reference, pain management options for various surgical procedures are presented according to region of the body rather than by the pathophysiological mechanisms involved. In all cases, however, preoperative psychological preparation and medication should be considered, and ongoing postoperative assessment and reassessment of pain should be routine. In this way, pain can be controlled effectively. Vigilance for changes in postoperative pain will trigger prompt searches for diagnostically significant causes of new pain.

## Head and Neck Surgery

### Dental surgery

The most common forms of dental surgery are brief and relatively noninvasive procedures often performed on an outpatient basis. A patient's anxiety is frequently disproportionate to the safety of the procedure; such a patient may benefit from behavioral or pharmacologic (anxiolytic) therapy. Mild pain associated with most forms of uncomplicated dental care such as simple tooth extractions, endodontic therapy, or scaling of the periodontal area or of a previously asymptomatic tooth is well managed by oral administration of an NSAID such as aspirin or ibuprofen. Preoperative administration of ibuprofen appears to delay the onset of postoperative pain and lessen its severity (Jackson, Moore, and Hargreaves, 1989). For patients unable to tolerate aspirin or ibuprofen, acetaminophen can provide an acceptable analgesic effect.

Dental procedures such as surgical removal of bony impactions and osseous periodontal surgery are more traumatic and typically produce intense and prolonged postoperative pain. The onset of such pain can be delayed by preoperative treatment with ibuprofen and/or application of a long-acting local anesthetic such as bupivacaine during the procedure.

Rarely, an intravascular or intraneural injection of local anesthetic in this context leads to bruising, bleeding, or systemic symptoms such as fainting, allergic reaction, or persistent pain due to direct nerve injury. When postoperative pain does emerge, it often requires the addition of an opioid to the nonsteroidal regimen. Codeine is frequently prescribed at a dosage of 30- 60 mg every 4-6 hours. Increased analgesia -- but also an increased number of opioid side effects such as nausea, constipation, sedation, and respiratory depression -- follow dosage increases above this level. Alternative opioids include propoxyphene or oxycodone administered in doses that are equianalgesic to 30-60 mg of codeine.

Some operations on the oral cavity preclude the patient's taking oral medications postoperatively (e.g., wiring the mouth closed after an operation on a mandibular fracture). Alternative therapy should be based on the severity of the surgical procedure and expected pain associated with it, as well as the surroundings in which it will be managed. Formulations of NSAIDs such as rectal suppositories (indomethacin) or intramuscular injection (ketorolac) are now commonly available. Opioids may be administered by a variety of routes (intravenous, intramuscular, subcutaneous injection, transdermal, rectal) and schedules, including a patient controlled schedule. Cost-efficacy analyses of parenteral opioid administration for oral surgery are not sufficient to permit any clear recommendations. Pain that does not respond to these measures should prompt a search for infection, osteitis, peripheral nerve injury, or the emergence of psychological and behavioral changes consistent with the development of chronic pain syndrome.

### Radical head and neck surgery

These operative procedures commonly interfere with oral intake for prolonged periods postoperatively and may be combined with a feeding gastrostomy or jejunostomy. Airway patency is always a consideration in these patients, and a tracheostomy frequently is an integral part of the operation. The use of flap coverage or skin grafts further increases the number of potentially painful sites. Prolonged preoperative pain, radiotherapy, and chemotherapy are important preoperative modifiers of pain therapy. Thus, the very nature of the operative procedure may dictate alternate routes for pain therapy in patients who have undergone major head and neck ablative procedures that may interfere with a patient's ability to describe pain and his or her response to analgesic intervention.

Intraoperative positioning of the head and neck are critical. Protective padding and avoidance of extreme flexion, extension, and rotation may help obviate or minimize muscle spasm-induced pain after surgery. Foam cushion supports under the occiput can minimize decubitus, pressure- induced headache, palsies, and causalgia. Intraoperative traction on muscles and nerves should be started carefully and monitored during the operation to prevent reflex myalgias and causalgias. Painful swallowing after head and neck; ear, nose, and throat; and endocrine surgical procedures may require elixir (i.e., liquid) forms of pain medicine, a modified diet, including liquid or soft foods, and occasional use of topical anesthetics such as viscous lidocaine.

Postoperative pain is often short term and of moderate intensity. Within 1-3 days, parenteral and oral opioids can be discontinued or replaced with non-opioid analgesics (which may have to be delivered via gastrostomy or jejunostomy). The use of most NSAIDs may be contraindicated for such procedures as thyroidectomy and parathyroidectomy where postoperative hemorrhage and risk of airway obstruction are significant. In such cases, acetaminophen or "platelet- sparing" NSAIDs may be ordered.

### Neurosurgery

Patients undergoing an operation on the central nervous system frequently show abnormal neurologic signs and symptoms that must be closely followed in the postoperative period. In addition, these patients may receive drugs designed to reduce cerebral edema or prevent seizures. A major dilemma in this clinical setting is the need to carefully monitor critical neurologic signs such as pupillary reflexes and the level of consciousness that may be affected by conventional opioid analgesics used for the relief of postoperative pain.

Ideally, postoperative pain control should not interfere with the ability to assess a patient's neurologic status, particularly the level of consciousness, or with assessment of motor and sensory function following spinal cord surgery. Therefore, the administration of opioids, benzodiazepines, and anxiolytics, in particular, is relatively contraindicated. However, the clinician must balance the need for analgesia with the requirement for appropriate neurologic monitoring.

The uncomplicated postcraniotomy patient typically has mild to moderate pain and is readily managed by a short period of parenteral medications followed by oral analgesics. Laminectomy and other spinal procedures usually are more painful than craniotomies. Ketorolac, a parenteral NSAID, may be considered in this setting because it has no effect on the level of consciousness or pupillary reflexes. As mentioned previously, the use of nonsteroidal analgesics may be contraindicated in some postoperative settings when the risk of coagulopathy or hemorrhage is high, the need to assess fever is important, or when the degree of pain is higher than the analgesic ceiling of the agent.

Epidural opioids and/or local anesthetics can minimize the need for systemic opioids and allow more accurate monitoring of brainstem and cerebral function. However, a single dose of epidural morphine may produce significant blood concentrations (Max, Inturrisi, Kaiko, Grabinski, Li, and Foley, 1985) that in turn cause effects within the central nervous system. A recent study could not demonstrate a difference in neuropsychiatric functioning between patients receiving oral and epidural morphine (Sjogren, and Banning, 1989). Furthermore, motor and sensory dysfunction associated with epidural local anesthetics (which are often coadministered with opioids) may obscure important neurologic signs. Again, remember to balance the need for adequate analgesia while minimizing the confounding central nervous system effects of analgesics and anesthetics.

## Chest and Chest Wall Surgery

### Thoracic surgery (noncardiac)

Operative sites within the thorax include the heart, esophagus, and lungs and somatically innervated structures such as the ribs, superficial chest wall, and breast. Preexisting disease of these organs (e.g., chronic obstructive pulmonary disease) or prior medical treatment (e.g., chemotherapy) are common. They contribute to postoperative morbidity through a variety of mechanisms, such as decreased pulmonary reserve. Drains and chest tubes can cause intense irritation and pain at entry sites or deeper. For this reason, NSAIDs such as indomethacin in suppository form are useful to reduce inflammation although they are rarely enough for complete pain relief and indeed are not approved by the Food and Drug Administration as simple analgesics.

Good evidence exists that aggressive pain control in the form of epidural analgesia or neural blockade with local anesthetics after thoracic surgery improves pulmonary function; however, at present there is insufficient evidence from randomized controlled trials (RCTs) to conclude that these forms of aggressive pain control after thoracic surgery hasten walking or reduce morbidity and length of hospital stay (Guideline Report, in press ; Hasenbos, van Egmond, Gielen, and Crul, 1987 ; Kaplan, Miller, and Gallagher, 1975 ; Sabanthan, Mearns, Bickford Smith, Eng, Berrisford, Bibby, and Majid, 1990 ; Shulman, Sandler, Bradley, Young, and Brebner, 1984).

The greatest beneficial effects result from administration of opioids or a combination of opioid and local anesthetic in the thoracic epidural space. Reliance on a local anesthetic alone to secure postoperative epidural analgesia in the thoracic region carries possible side effects such as hypotension due to sympathetic blockade. Respiratory impairment because of somatic nerve block is another potential problem; therefore, intercostal nerve blocks are generally undesirable unless an opioid is contraindicated. Mixing a local anesthetic with an opioid produces better and more prolonged analgesia, but RCTs indicate that there is a tendency toward more side effects when an opioid is added to a local anesthetic, compared with the local anesthetic alone (Guideline Report, in press ; Capogna, Celleno, Tagariello, and Loffreda- Mancinelli, 1988 ; Pybus, D'Bras, Goulding, Liberman, and Torda, 1983). An example of a coordinated approach to postoperative analgesia is the placement of an epidural catheter prior to induction of anesthesia, which is used to deliver local anesthesia, either alone or mixed with an opioid for intraoperative analgesia, and then left in place postoperatively for infusion of a dilute analgesic. As previously emphasized, monitoring and care of patients with epidural catheters and assessment of the optimal time for switching to oral analgesia are best accomplished by a specially trained team.

Direct injection of local anesthetics alone to block intercostal nerves has been done for years as a means to provide postoperative analgesia and improved pulmonary function after thoracotomy. Unfortunately, such analgesia lasts only 6 to 12 hours, so that a single injection rarely suffices for the entire postoperative period. A clinician can overcome the brief duration of intercostal anesthesia by administering interpleural local anesthetics. To accomplish this, a catheter is placed between the parietal and visceral pleura, and anesthetic is injected at 4- to 6-hour intervals or infused continuously to produce continuous analgesia across several dermatomes (Scott, Mogensen, Bigler, and Kehlet, 1989). As in all invasive techniques, this method requires skill in drug titration and vigilance for management of side effects such as pneumothorax.

The use of opioids to reduce postoperative pain after thoracotomy is well documented. Because of potential side effects, clinicians have tried to optimize delivery and closely match dose to need. In this context, PCA has resulted in incrementally improved analgesia, increased patient satisfaction, and tendencies towards improved pulmonary function and earlier recovery or discharge (Guideline Report, in press ; Eisenach, Grice, and Dewan, 1988 ; Jackson, 1989 ; McGrath, Thurston, Wright, Preshaw, and Fermin, 1989 ; Wasylak, Abbott, English, and Jeans, 1990). One strategy to manage pain after thoracotomy is to deliver epidural analgesia to prevent pain and then switch to patient controlled intravenous analgesia if the epidural catheter ceases to function or is discontinued after several days on the ward.

A typical prescription for intravenous PCA in this setting relies first on a series of "loading" doses: for example, 3-5 mg of morphine, repeated every 5 minutes until the initial postoperative pain diminishes. A low-dose basal infusion at night (e.g., 0.5-1.0 mg/hr) allows uninterrupted sleep for the patient. On-demand doses typically add 0.5-1.5 mg of morphine every 6 minutes. PCA doses of opioid are valuable to supplement analgesia during respiratory therapy or ambulation, even after the patient is taking oral analgesics and especially while chest tubes are in place. The transition from intravenous PCA to oral opioids is accomplished as described above (p. 20). If adequate opioid analgesia yields undesired side effects, or if pain is not severe (e.g., when chest tubes are no longer in place), the patient can switch directly from epidural to oral analgesia using a combination of opioid and NSAID. Many opioid analgesics or mixtures are available in liquid form and are useful for patients unable to swallow tablets or capsules (e.g., after esophageal surgery).

### Cardiac surgery

Most cardiac operations involve a median sternotomy and anesthetic induction using high doses of opioids (morphine at 1 mg/kg or another opioid at an equivalent dose). Because somatic nerves are not divided by the surgical incision, postoperative pain is usually less than after conventional thoracotomy, even when lower doses of opioids are given during surgery. For procedures that use intercostal incisions, such as implantation of automatic defibrillatory devices, methods of pain control need not differ from those of other thoracic operations. Close observation is essential to distinguish postoperative pain originating in the chest wall and pleura from cardiac pain, which may signal myocardial ischemia due to a tachyrhythmia or threatened infarction from inadequate revascularization.

## Abdominal and Perineal Surgery

### Upper abdominal surgery (includes cholecystectomy, aortic bypass)

Although outside the thorax, operations on the upper abdomen such as cholecystectomy compromise pulmonary function. Other associated morbidity (that may lead to mortality) includes immobility, hypercoagulability, venous thrombosis, and increased myocardial oxygen consumption when pain leads to an increase in blood pressure or rapid heart rate. Patients who undergo major vascular surgery frequently have coexisting myocardial disease, wide swings in blood pressure as their major vessels are clamped and unclamped, and significant fluid shifts associated with blood loss and replacement. These patients are particularly at risk for postoperative myocardial infarctions and arrhythmias. For operations on the abdominal aorta, intraoperative epidural anesthesia is widely used and simplifies the transition to postoperative epidural analgesia through the same catheter.

Hormonal indexes of stress are reduced postoperatively in patients given epidural analgesia using a local anesthetic (e.g., 0.25% bupivacaine) such as after cholecystectomy. Yet even when pain is completely eliminated by this technique, these hormonal stress responses do not vanish (Analgesia and the metabolic, Normally, a minimum of 3 or 4 days will elapse postoperatively before oral analgesia is feasible following operations on the biliary system, stomach or intestine, or vasculature in the upper abdomen.

In preparing the patient for any upper abdominal operation, choices of pain management to be reviewed with the patient include: intramuscular or subcutaneous injection of an opioid as needed, a "round-the-clock" schedule of injections (or continuous infusion of opioid) to be withheld in the event of side effects such as respiratory depression or nausea, intravenous PCA, or epidural analgesia in the manner described for postthoracotomy pain. Each of these approaches carries its own risks and benefits, which depend on the health care team's knowledge, expertise, and ability to recognize and treat side effects and correct inadequate pain relief. Other techniques have been used for post-cholecystectomy pain, such as interpleural catheters or supplemental, long-acting local anesthetic blocks of the lower intercostal nerves and celiac plexus. These lie outside the range of most current clinical practice.

### Lower abdominal and perineal surgery (includes abdominal hysterectomy, cesarean section, hernia repair, episiotomy, urological, and gynecological procedures, and hemorrhoidectomy)

The pain management plan for the patient undergoing lower abdominal or perineal surgery is based on the same principles as those for patients undergoing upper abdominal procedures. On the other hand, analgesia to control pain of active labor must be approached with special expertise and caution in light of side effects that may impair fetal well-being (e.g., fetal respiratory depression after maternal opioids or maternal hypotension after epidural local anesthetic). Suppression of pain and surgical stress responses is more complete with epidural local anesthesia after lower abdominal surgery than after upper abdominal operations (Kehlet, 1989b). Presumably this is because pathways such as phrenic or thoracic somatosensory afferents are less easily blocked by epidural anesthesia. Many obstetrical or urological procedures (e.g., cystoscopy) routinely are performed using spinal or epidural anesthesia, and the addition of low doses of opioid to a local spinal anesthetic appears to lengthen the duration of analgesia observed after the local anesthetic effect has subsided (Capogna, Celleno, Tagariello, and Loffreda-Mancinelli, 1988 ; Chawla, Arora, Saksena, and Gode, 1989 ; Hanson, Hanson, and Matousek, 1984 ; Pybus, D'Bras, Goulding, Liberman, and Torda, 1983 ; Reay, Semple, Macrae, MacKenzie, and Grant, 1989). Pain after procedures on the anus is particularly severe and requires adjunctive measures such as stool softeners, dietary manipulation, and local anesthetic suppositories for control. Again, the precautions already outlined concerning spinal opioid use and the necessity for close monitoring apply. Goals of the postoperative pain management plan should include early ambulation. For obstetric procedures, opioid doses should be adjusted so as to produce minimum maternal and fetal sedation. Alternatively, if an epidural catheter has been placed for infusion of local anesthetic to control labor pain or to provide anesthesia for cesarean section, a dilute solution of local anesthetic may be infused through this catheter to control postoperative pain with little risk of sedating the nursing infant.

## Musculoskeletal Surgery

### Back surgery

Operations on the spine at any level are frequently done in patients who have experienced chronic pain. Such patients may have the typical complications of chronic pain: depression, anxiety, irritability, and if opioid analgesics were required preoperatively, a relative tolerance to opioid medications. All of these factors may complicate pain assessment and treatment in the postoperative period. In addition, the majority of procedures requiring a spinal operation are associated with paraspinal muscle spasm. In such cases, it is appropriate to add muscle relaxants to supplement conventional opioid therapy.

Operations on the spinal cord often involve laminectomy and bone grafting and may include opening the dura around the spinal cord. These procedures may limit the role of epidural and spinal delivery of pain medications. As with any neurologic procedure, postoperative patients require careful monitoring of neurologic functions, especially the assessment of sensory, motor, and autonomic functioning.

### Surgery on extremities (orthopedic, vascular)

Many common operations performed on extremities are elective and include total joint replacements. The high degree of morbidity related to venous thromboembolic complications must be considered. Pain control postoperatively should allow early ambulation and movement in the postoperative period. Supplementing conventional opioids with an epidural infusion of a local anesthetic may benefit these patients by decreasing the incidence of thromboembolism. Operations requiring a cast or other form of external fixation for stabilization demand frequent postoperative evaluation of circulation and neurologic functions. Pain therapy should not interfere with monitoring the patient.

Orthopedic or vascular procedures on an extremity may result in a compartment syndrome; this is usually associated with a period of ischemia or perhaps injury to the muscles of the lower extremity. It is manifested by intracompartmental swelling with loss of function, the earliest manifestation being loss of dorsiflexion of the foot and pain. Once again, this requires continuous observation; pain control measures should not mask this process. If not treated promptly by decompression, a compartment syndrome may result in chronic postischemic neuropathy.

The traumatic amputation is often associated with phantom limb pain. Evidence now exists that infusion of epidural local anesthetic prior to elective amputation for inoperative vascular disease can minimize this symptom (Bach, Noreng, and Tjellden, 1988); the applicability of these pilot data to treatment of other conditions or trauma remains to be defined.

The majority of operative procedures on extremities produce pain of moderate intensity usually controlled by early parenteral opioids supplemented by NSAIDs. Adding epidural analgesia is particularly attractive in terms of establishing early mobility and minimizing thromboembolic complications (Guideline Report, in press ; Modig, Borg, Bagge, and Saldeen, 1983 ; Modig, Borg, Karlstrom, Maripuu, and Sahlstedt, 1983 ; Pettine, Wedel, Cabanela, and Weeks, 1989).

## Soft Tissue Surgery

Surgical procedures involving local soft tissue resections usually obtain pain control with oral opioids. Many of these procedures are done on an ambulatory basis and require careful patient education prior to and immediately after the procedure. Anxiety because of the potential results of a small surgical biopsy (e.g., feared results of a breast biopsy) may demand adjuvant drug or nondrug therapy. Pre- and postoperative education and support by the surgeon and the health care team are supremely important.