# Options to Prevent and Control Postoperative Pain

Patient education and reduction of any preexisting pain should occur before the operation. Because the goal of the treatment plan is to prevent significant postoperative pain from the outset, treatment alternatives, potential risks, dosage adjustments, and adjunctive therapies should be described to the patient and family. Teaching emphasizes what the patient is likely to experience postoperatively, including the specific method(s) of pain assessment, intervention(s) the staff will employ, and the level of patient participation required. Staff also should inform patients that it is easier to prevent pain than to "chase" or treat it once it has become established, and that communication of unrelieved pain is essential to its relief.

Pain control options include:

- Cognitive-behavioral interventions such as relaxation, distraction, and imagery; these can be taught preoperatively and can reduce pain, anxiety, and the amount of drugs needed for pain control;
- Systemic administration of nonsteroidal anti-inflammatory drugs (NSAIDs) or opioids using the traditional "as needed" schedule or around-the-clock administration (American Pain Society, 1989);
- Patient controlled analgesia (PCA), usually meaning self-medication with intravenous doses of an opioid; this can include other classes of drugs administered orally or by other routes;
- Spinal analgesia, usually by means of an epidural opioid and/or local anesthetic injected intermittently or infused continuously;
- Intermittent or continuous local neural blockade (examples of the former include intercostal nerve blockade with local anesthetic or cryoprobe; the latter includes infusion of local anesthetic through an interpleural catheter);
- Physical agents such as massage or application of heat or cold; and
- Electroanalgesia such as transcutaneous electrical nerve stimulation (TENS).

A postoperative pain management plan might include several of these options. A pamphlet, or "menu" of alternative strategies, can help focus discussion of these options between caregivers and the patient. The postoperative pain management plan should reflect coexisting and/or ongoing problems such as cancer-related pain or opioid tolerance. The plan should be consistent with the overall surgical and anesthetic plans. For example, an elixir form of analgesic is preferable to a tablet when painful or difficult swallowing is anticipated. Also, if the patient is to have an epidural catheter placed during surgery that could make postoperative pain control simpler or more effective, it should not be removed in the Post-Anesthesia Care Unit (PACU). Staff should note their plans for pre-, intra-, and postoperative pain management in the patient's chart so that other members of the care team can respond to patient questions and coordinate plans for rehabilitation and discharge.

Intraoperative management is often key to the success of postoperative pain control. If pain prevention and control are to be achieved through an epidural catheter, the catheter should be placed and its function verified preoperatively to assure its effective intra- and postoperative use. This is particularly true in patients whose position, body casts, or subsequent anticoagulation make postoperative catheter insertion problematic. The planned pre- and intraoperative use of opioids, and timing of the first postoperative opioid dose by the anesthesiologist, nurse anesthetist, surgeon, or PACU nurse are important in the postoperative care plan. Equally important are decisions during surgery on the concurrent use of local anesthetics (e.g., for intraoperative nerve blocks) and the nature of the surgical incision and placement of drains or tubes (e.g., chest, and nasogastric). If TENS is to be used for postoperative pain management, the electrodes may need to be placed intraoperatively. Finally, intraoperative placement of casts and splints to provide support and restrict postoperative movement may enhance other pain management efforts.

## Pharmacologic Management

Pharmacologic management of mild to moderate postoperative pain should begin, unless there is a contraindication, with an NSAID. Moderately severe to severe pain normally should be treated initially with an opioid analgesic. After many relatively noninvasive surgical procedures, NSAIDs alone can achieve excellent pain control (Davie, Slawson, and Burt, 1982 ; Rosen, Absi, and Webster, 1985). NSAIDs decrease levels of inflammatory mediators generated at the site of tissue injury. Even when insufficient alone to control pain, NSAIDs have a significant opioid dose-sparing effect upon postoperative pain and can be useful in reducing opioid side effects (Guideline Report, in press ; Hodsman, Burns, Blythe, Kenny, McArdle, and Rotman, 1987 ; Martens, 1982). The concurrent use of opioids and NSAIDs often provides more effective analgesia than either of the drug classes alone. Although it is likely that NSAIDs also act within the central nervous system, in contrast to opioids, they do not cause sedation or respiratory depression, nor do they interfere with bowel or bladder function. Acetaminophen does not affect platelet aggregation, nor does it provide peripheral anti- inflammatory activity. Some evidence exists that two salicylates do not affect platelet aggregation profoundly; these are salsalate (Estes, and Kaplan, 1980) and choline magnesium trisalicylate (Danesh, Saniabadi, Russell, and Lowe, 1987). All other NSAIDs appear to produce a risk of platelet dysfunction that may impair blood clotting and carry a small risk of gastrointestinal bleeding. At present, one NSAID (ketorolac) is approved by the Food and Drug Administration for parenteral use. The analgesic dosage tables in appendixes B and C include information on NSAIDs, opioids, and other analgesic drugs.

Opioid analgesics are the cornerstone of pharmacological postoperative pain management, especially for more extensive surgical procedures that cause moderate to severe pain. Other agents such as NSAIDs or single injections of local anesthetics may control mild to moderate pain after relatively minor procedures or reduce opioid dose requirements after more extensive operations when this is a goal (Guideline Report, in press ; Egan, Herman, Doucette, Normand, and McLeod, 1988 ; Engberg, 1985a, 1985b ; Kaplan, Miller, and Gallagher, 1975 ; Patel, Lanzafame, Williams, Mullen, and Hinshaw, 1983 ; Sabanathan, Mearns, Bickford Smith, Eng, Berrisford, Bibby, and Majid, 1990 ; Toledo-Pereyra, and DeMeester, 1979). Even in the absence of preemptive efforts targeted at postoperative analgesia, adequate postoperative pain control can usually be achieved with opioid analgesics. When increasing doses of opioids are ineffective in controlling postoperative pain, a prompt search for residual pathology is indicated, and other diagnoses such as neuropathic pain should be considered.

Opioid tolerance or physiological dependence is unusual in short-term postoperative use in opioid naive patients. Likewise, psychologic dependence and addiction are extremely unlikely to develop after patients without prior drug abuse histories use opioids for acute pain (Porter, and Jick, 1980). Proper use of opioids involves selecting a particular drug and route of administration and judging: 1) suitable initial dose; 2) frequency of administration; 3) optimal doses of non- opioid analgesics, if these are also to be given; 4) incidence and severity of side effects; and 5) whether the analgesic will be given in an inpatient or ambulatory setting. Titration to achieve the desired therapeutic effect in the immediate postoperative period and to maintain that effect over time should be emphasized.

Opioids produce analgesia by binding to opioid receptors both within and outside the central nervous system. Opioid analgesics are classified as full agonists, partial agonists, or mixed agonist-antagonists, depending on the manner in which they interact with opioid receptors. Full agonists produce a maximal response within the cells to which they bind; partial agonists produce a lesser response, regardless of their concentration; and mixed agonist- antagonists activate one type of opioid receptor while simultaneously blocking another type. Several types and subtypes of such receptors exist. The most important receptor type for clinical analgesia is named "mu" because of its affinity for morphine. Other commonly used mu opioid agonists include hydromorphone, codeine, oxycodone and hydrocodone, methadone, levorphanol, and fentanyl. All mu opioid agonists have the potential to cause constipation, urinary retention, sedation, and respiratory depression and frequently also produce nausea or confusion. Mixed agonist- antagonists in clinical use include pentazocine [Talwin], butorphanol tartrate [Stadol], and nalbuphine hydrochloride [Nubain]; each of these blocks or is neutral at the mu opioid receptor while simultaneously activating a different type of opioid receptor termed "kappa." Patients receiving mu opioid agonists should not be given a mixed agonist- antagonist because doing so may precipitate a withdrawal syndrome and increase pain. Mixed agonist-antagonists and partial agonists may exhibit a ceiling effect not only with respect to respiratory depression (Nagashima, Karamanian, Malovany, Radnay, Ang, Koerner, and Foldes, 1976 ; Kallos, and Caruso, 1979) but also in regard to their analgesic activity. In the awake patient, there is a clinical ceiling analgesic effect even with morphine because side effects such as respiratory depression limit the dose that may be safely given. However, this does not limit the ability of clinicians to effectively increase the drug dose when the painful stimulus increases and respiratory status is monitored.

Meperidine [Demerol], a mu opioid analgesic, is commonly used for postoperative pain control. Meperidine is commonly underdosed and administered too infrequently even by physicians aware of its pharmacokinetics (Marks, and Sachar, 1973). The common postoperative meperidine order of 75 mg parenterally every 4 hours as needed often is inadequate for several reasons. Meperidine produces clinical analgesia for only 2.5-3.5 hours, and a dose of 75 mg every 4 hours is equivalent to only 5- 7.5 mg of morphine. Therefore, to obtain postoperative analgesia equal to that from 10 mg of morphine sulfate every 4 hours, a clinician would have to use 100-150 mg of meperidine every 3 hours. Because of its unique toxicity, meperidine is often contraindicated in patients with impaired renal function and those receiving antidepressants of the monamine oxidase inhibitor class (Wood, and Cousins, 1989). Normeperidine (6-N-desmethylmeperidine) is a toxic meperidine metabolite excreted through the kidney. In patients with normal renal function, normeperidine has a half-life of 15 to 20 hours; this time is extended greatly in elderly individuals and patients with impaired renal function. Normeperidine is a cerebral irritant that can cause effects ranging from dysphoria and irritable mood to convulsions (Kaiko, Foley, Grabinski, Heidrich, Rogers, Inturissi, and Reidenberg, 1983 ; Szeto, Inturrisi, Houde, Saal, Cheigh, and Reidenberg, 1977). These effects have been observed even in young, otherwise healthy patients given sufficiently high doses of normeperidine postoperatively. Therefore, meperidine should be reserved for very brief courses in otherwise healthy patients who have demonstrated an unusual reaction (e.g., local histamine release at the infusion site) or allergic response during treatment with other opioids such as morphine or hydromorphone.

Titration of opioids should be based on the patient's analgesic response and side effects. Remember that patients vary greatly in their analgesic dose requirements and responses to opioid analgesics. Relative potency estimates provide a rational basis for selecting the appropriate starting dose to initiate analgesic therapy, changing the route of administration (e.g., from parenteral to oral), or when switching to another opioid. Dosage conversion factors based on relative potency estimates may differ somewhat between individual patients. When estimating the initial postoperative dose of an opioid analgesic, a clinician should consider whether patients have been receiving opioid analgesics preoperatively. In such patients, supplemental postoperative doses should be adjusted above the preoperative baseline requirement unless the operation itself is likely to remove the painful stimulus.

An "as-needed" order for opioid administration can result in prolonged delays while the nurse unlocks the controlled substances cabinet and prepares the drug for administration and until the drug takes effect. These delays can be eliminated by administering analgesics on a regular time schedule initially. For example, if the patient is likely to have pain requiring opioid analgesics for 48 hours following surgery, morphine could be ordered every 4 hours by the clock (not "as needed") for 36 hours. Once the duration of analgesic action is determined for a patient, the dosage frequency should be adjusted to prevent pain from recurring. Depending on patient preferences, the orders may be written so that the patient can refuse an analgesic if not in pain or forego it if asleep. However, as in dosing with other drugs that require a steady blood level to remain effective, interruption of an around-the-clock dosage schedule during the hours of sleep may cause the patient to be suddenly awakened by intense pain as blood analgesic levels decline.

It may be acceptable late in the postoperative course to give the same drug every 4 hours as requested. Switching from an around-the-clock to an as- needed dosage schedule later in the patient's course is one way to provide pain relief while minimizing the risk of adverse effects as the patient's analgesic dose requirement diminishes. As part of this schedule, a patient's pain should be assessed at regular intervals to determine the efficacy of the drug intervention, the presence of side effects, or the need for dosage adjustment or supplemental doses for breakthrough pain. Effective use of opioid analgesics should facilitate routine postoperative activities -- e.g., coughing and deep breathing exercises, ambulation, and physical therapy (Alexander, Parikh, and Spence, 1973 ; Rawal, and Sjostrand, 1986 ; Wasylak, Abbott, English, and Jeans, 1990). The opioid should be withheld if the patient is sedated when awake or whenever there is respiratory depression (usually fewer than 10 breaths per minute).

Opioids may be administered by a variety of routes; oral dosing is usually the most convenient and least expensive route of administration. It is appropriate as soon as the patient can tolerate oral intake and is the mainstay of pain management in the ambulatory surgical population.

Preoperative intravenous or epidural access may be appropriate for postoperative management of severe pain, even when the oral route is available. Relatively few side effects will occur ordinarily, providing that these modalities are carefully managed by clinicians with appropriate expertise. Using potent analgesics or invasive techniques postoperatively, at a time when a patient's level of consciousness and physical function are returning to normal, requires careful titration and patient assessment.

Drug dosage, frequency, side effects, and risks differ even more noticeably between the intravenous and epidural routes than between the oral and intravenous routes. Clinicians not familiar with epidural opioid doses and pharmacokinetics must review the literature carefully before using that route. In addition, side effects (e.g., confusion, respiratory depression, hypotension, urinary retention, or pruritus) associated with opioids can be greater with intravenous and epidural administration and require ongoing assessment and monitoring. Other potential problems that dictate expert vigilance and followup during epidural analgesia include abscess development or anesthesia of a nerve root at the site of catheter tip. These routes of administration are best limited to specially trained staff who are knowledgeable and skilled in the management of patients receiving intravenous or epidural opioids, typically under the direction of an acute or postoperative pain treatment service.

Patient controlled analgesia is a safe method for postoperative pain management that many patients prefer to intermittent injections. Systemic PCA usually connotes intravenous drug administration, but it also can be subcutaneous or intramuscular. Few studies of the use of PCA drug delivery to the epidural space exist. A typical intravenous PCA prescription applicable to many contexts relies on a series of "loading" doses; for example, 3-5 mg of morphine, repeated every 5 minutes until the initial postoperative pain (if present) diminishes. A low-dose basal infusion (0.5-1 mg/hr) at night allows uninterrupted sleep. On-demand doses typically add 1 mg of morphine every 6 minutes, with a total hourly limit of 10 mg. Once the patient is able to take oral medications, an around-the-clock schedule of an oral opioid such as a codeine-acetaminophen combination is provided, and the basal infusion rate is discontinued. By observing the number of "on-demand" doses self- administered by the patient, the clinician can assess the adequacy of the oral medication and titrate it further, change to a stronger compound such as oxycodone with acetaminophen, or discontinue the PCA pump.

Intravenous administration is the preferred route for postoperative opioid therapy when the patient cannot take oral medications. When intravenous access is problematic, sublingual and rectal routes should be considered as alternatives to traditional intramuscular or subcutaneous injections. All routes other than intravenous require a lag time for absorption of the drug into the circulation. In addition, repeated injections with associated pain and trauma may deter some patients, especially children, from requesting pain medication. Continuous administration of low doses of opioids intravenously or transdermally and intermittent delivery across the buccal mucosa are relatively new but apparently effective methods to administer opioids postoperatively. Further experience is needed to define the clinical roles of these innovative methods in relation to more well-established methods.

Patient controlled analgesia (PCA) is a safe method for postoperative pain management that many patients prefer to intermittent injections.

Opioids and local anesthetic agents interact favorably. Continuous administration into the epidural space of low concentrations of opioids in dilute solutions of local anesthetic provides excellent analgesia, while reducing the potential risks (e.g., respiratory depression or motor block) associated with equianalgesic concentrations of either agent administered singly. In a less technologically demanding approach, systemically administered opioids given pre-, intra-, or postoperatively augment the duration and effectiveness of local anesthetics given spinally or epidurally. Local anesthetics alone may be applied intermittently to specific nerves to interrupt pain pathways. For example, injecting local anesthetics around the intercostal nerves after thoracotomy significantly improves pulmonary function (Guideline Report, in press ; Engberg, 1985b ; Kaplan, Miller, and Gallagher, 1975 ; Toledo- Pereyra, and DeMeester, 1979). Catheters for continuous or repeated intermittent dosing of local anesthetic also have been employed postoperatively in the pleural space or adjacent to nerves such as the brachial plexus or cervical sympathetic ganglia. However, a clinical role for interpleural or perineural local anesthetics in the postoperative setting has not yet been defined.

## Nonpharmacologic Management

Nonpharmacologic interventions can be classified as either cognitive- behavioral interventions or physical agents. Cognitive and behaviorally based approaches include several ways to help patients understand more about their pain and take an active part in its assessment and control. The goals of interventions classified as cognitive-behavioral therapies are to change patients' perceptions of pain, alter pain behavior, and provide patients with a greater sense of control over pain. The goals of interventions classified as physical agents or modalities are to provide comfort, correct physical dysfunction, alter physiological responses, and reduce fears associated with pain-related immobility or activity restriction. Nonpharmacologic approaches are intended to supplement, not substitute for, the pharmacologic or invasive techniques described above.

Nonpharmacologic interventions are appropriate for the patient who: 1) finds such interventions appealing; 2) expresses anxiety or fear, as long as the anxiety is not incapacitating or due to a medical or psychiatric condition that has a more specific treatment; 3) may benefit from avoiding or reducing drug therapy (e.g., history of adverse reactions, fear of or physiological reason to avoid oversedation); 4) is likely to experience and need to cope with a prolonged interval of postoperative pain, particularly if punctuated by recurrent episodes of intense treatment- or procedure-related pain; or 5) has incomplete pain relief following appropriate pharmacologic interventions. Cognitive- behavioral approaches include preparatory information, simple relaxation, imagery, hypnosis, and biofeedback. Physical therapeutic agents and modalities include application of superficial heat or cold, massage, exercise, immobility, and electroanalgesia such as TENS therapy.

Giving a patient a detailed description of all medical procedures, expected postoperative discomfort, and instruction aimed at decreasing treatment- and mobility-related pain can decrease self-reported pain, analgesic use, and postoperative length of stay (Guideline Report, in press ; Egbert, Battit, Welch, and Bartlett, 1964 ; Fortin, and Kirouac, 1976 ; Schmitt, and Wooldridge, 1973 ; Voshall, 1980). Patients should receive sufficient procedural and sensory information to satisfy their interest and enable them to assess, evaluate, and communicate postoperative pain. In addition, all preoperative patients should receive instruction emphasizing the importance of coughing, deep breathing, turning, and walking, along with suggestions on how to decrease physical discomforts from such activities. When fear or anxiety occur, it is important to assess psychological coping skills and provide practical suggestions for managing pain and maintaining a positive outlook. Patients who appear anxious or fearful before surgery, and others who express an interest in cognitive-behavioral strategies, should be assisted in selecting an intervention (e.g., simple relaxation or imagery) and taught how to use it. In some patients, particularly those with high levels of anxiety, too much information, or too many demanding decisions can exacerbate fear and pain (Johnson, Fuller, Endress, and Rice, 1978 ; Johnson, Rice, Fuller, and Endress, 1978). Psychiatric evaluation is appropriate for patients who manifest disabling or disruptive anxiety symptoms such as emotional instability, restlessness, inability to sleep, and dulled thinking.

Relaxation is the most widely evaluated cognitive-behavioral approach to postoperative pain management. Relaxation strategies, including simple relaxation (Horowitz, Fitzpatrick, and Flaherty, 1984 ; Lawlis, Selby, Hinnant, and McCoy, 1985 ; Levin, Malloy, and Hyman, 1987); imagery (Daake, and Gueldner, 1989 ; Horan, Laying, and Pursell, 1976); hypnosis (Kiefer, and Hospodarsky, 1980); biofeedback (Madden, Singer, Peck, and Nayman, 1978); and music-assisted relaxation (Locsin, 1981 ; Mullooly, Levin, and Feldman, 1988), have all shown some degree of effectiveness in reducing pain. Relaxation strategies and imagery techniques need not be complex to be effective. Relatively simple approaches such as the brief jaw relaxation procedure described on page 25 have been successful in decreasing self- reported pain and analgesic use (Flaherty, and Fitzpatrick, 1978 ; Wells, 1982). These strategies take only a few minutes to teach but require periodic reinforcement through encouragement and coaching. Supportive family members or audiotapes often can sustain patient skills. [Sample relaxation and imagery exercises are included in appendix B and printed resource materials or manuals are available elsewhere (McCaffery, and Beebe, 1989 ; Syrjala, 1990).] A relaxation strategy that can be used informally is music distraction. Both patients' personally preferred music (Locsin, 1981) and "easy listening" music (Mullooly, Levin, and Feldman, 1988) have significantly decreased postoperative pain in clinical studies. Patients who need repeated coaching may benefit from the use of a commercially prepared relaxation or music- assisted relaxation audiotape.

Other cognitive-behavioral strategies require greater professional involvement; these include complex imagery, hypnosis, biofeedback, and combined therapies. Such strategies are commonly applied when patients have chronic pain even before surgery.

Examples of Nonpharmacologic Interventions for Postoperative Pain

Cognitive-Behavioral | Physical Agents
Education/instruction | Applications of heat or cold
Relaxation | Massage, exercise, and immobilization
Imagery
Music distraction | Transcutaneous electrical nerve stimulation
Biofeedback

Jaw Relaxation Instructions

- Let your lower jaw drop slightly, as though you were starting a small yawn.; - Keep your tongue quiet and resting on the bottom of your mouth.; - Let your lips get soft.; - Breathe slowly, evenly, and rhythmically: inhale, exhale, and rest.; - Allow yourself to stop forming words with your lips and stop thinking in words.

Although some data suggest that the use of complex imagery may reduce pain (Daake, and Gueldner, 1989 ; Horan, Laying, and Pursell, 1976), that biofeedback may lessen pain and operative site muscle tension (Madden, Singer, Peck, and Nayman, 1978 ; Moon, and Gibbs, 1984), and that interventions which combine imagery and relaxation may decrease pain (Mogan, Wells, and Robertson, 1985 ; Pickett, and Clum, 1982 ; Swinford, 1987), each requires specialized training and, for biofeedback, the use of special equipment. Findings from studies of hypnosis for control of postoperative pain are inconsistent (Daniels, 1976 ; John, and Parrino, 1983 ; Kiefer, and Hospodarsky, 1980 ; Snow, 1985). Insufficient research to demonstrate effectiveness in reducing postoperative pain and the need for special training or equipment preclude the recommendation of complex imagery, biofeedback, or hypnosis for routine postoperative pain control. This is not to say that patients who have a high level of preoperative anxiety, whose pain is severe and enduring, or who suffer recurrent episodes of procedure-related pain will not benefit from these strategies. However, for such patients a more comprehensive pain management program must include active involvement of professionals skilled in cognitive-behavioral therapy and psychological assessment.

In addition to cognitive-behavioral interventions, several physical therapeutic methods can be used to manage pain (Lee, Itoh, Yang, and Eason, 1990). Commonly used physical agents include applications of heat and cold, massage, exercise, and rest or immobilization. Applications of heat or cold are used to alter pain threshold, reduce muscle spasm, and decrease congestion in an injured area. Applications of cold are used initially to decrease tissue injury response. Later, heat is used to facilitate clearance of tissue toxins and accumulated fluids. Massage and exercise are used to stretch and regain muscle and tendon length. Immobilization is used following many musculoskeletal procedures to provide rest and maintain the alignment necessary for proper healing. With the exception of applications of cold and immobilization, these interventions typically are not used following surgery unless complications occur or an extended postoperative course is expected. When physical modalities are used, it is often for a physiological goal other than pain relief. Of these modalities only cryotherapy (application of cold) has been evaluated in the literature (Cohn, Draeger, and Jackson, 1989 ; Lanham, Powell, and Hendrix, 1984 ; Rooney, Jain, McCormack, Bains, Martini, and Goldiner, 1986). Lanham and colleagues (1984) and Rooney and colleagues (1986) used cryotherapy in association with TENS therapy. There is insufficient evidence to suggest that cryotherapy alone is effective in reducing postoperative pain. Cryotherapy is different from cryoanalgesia (application of a cryoprobe to specific peripheral nerves), which has proven effective for post- thoracotomy pain (Guideline Report, in press).

TENS therapy is one physical modality for which there is some support. TENS therapy has been effective in reducing self-reported pain and analgesic use following abdominal surgery (Cooperman, Hall, Mikalacki, Hardy, and Sadar, 1977 ; Hargreaves, and Lander, 1989), orthopedic surgery (Jensen, Conn, Hazelrigg, and Hewett, 1985 ; Smith, Hutchins, and Hehenberger, 1983), thoracic surgery (Liu, Liao, and Lien, 1985 ; Rooney, Jain, McCormack, Bains, Martini, and Goldiner, 1986), mixed surgical procedures (Neary, 1981 ; Solomon, Viernstein, and Long, 1980 ; VanderArk and McGrath, 1975), and cesarean section (Davies, 1982 ; Smith, Guralnick, Gelfand, and Jeans, 1986). TENS therapy also has improved physical mobility following thoracic (Liu, Liao, and Lien, 1985 ; Warfield, Stein, and Frank, 1985) and orthopedic (Jensen, Conn, Hazelrigg, and Hewett, 1985 ; Smith, Hutchins, and Hehenberger, 1983) surgery. Both TENS therapy and sham TENS therapy (that is, application of electrodes without transmission of electric current) significantly reduced analgesic use and subjective reports of pain (Guideline Report, in press). No significant differences were found between TENS therapy and sham-TENS (Conn, Marshall, Yadav, Daly, and Jaffer, 1986 ; Hargreaves and Lander, 1989 ; Taylor, West, Simon, Skelton, and Rowlingson, 1983). Even though these findings suggest a placebo effect underlies the reduction of perceived pain and analgesic use during TENS therapy, beneficial effects do, in fact, result (Guideline Report, in press). The physical modalities of acupuncture and electroacupuncture also have been clinically evaluated in postoperative patients, with conflicting findings; no clear analgesic effect has been demonstrated (Evron, Schenker, Olshwang, Granat, and Magora, 1981 ; Facco, Manani, Angel, Vincenti, Tambuscio, Ceccherelli, Troletti, Ambrosio, and Giron, 1981 ; Hansson, and Ekblom, 1986 ; Wigram, Lewith, Machin, and Church, 1986).

How each patient's postoperative pain management program is designed and implemented will vary according to the type of medical facility and services available to support a pain management program. At the least, clinicians should be introduced to these methods so they recognize the benefits of cognitive-behavioral and physical interventions, know the indications for their use, and are able to provide information and counseling to patients. In addition, patients should have access to written information about available therapies, why and when to use them, and sources for self- management materials or professional consultations.

Catastrophic postoperative events are rarely, if ever, masked by any of the approaches to postoperative pain control previously described. Any sudden or unexplained change in pain intensity requires immediate evaluation by the surgeon. Likewise, a sudden increase in anxiety may signal cardiac or pulmonary decompensation and requires prompt medical or surgical assessment.

## Process of Effective Pain Management

### Postoperative pain management

As illustrated in the flow chart on page 10 (Figure 2), the process of postoperative pain management is ongoing. Following intraoperative anesthesia and analgesia, postoperative pain assessment and management begin. Based on the preoperative plan, postoperative drug and nondrug interventions are initiated. Patients should be reassessed at frequent intervals (not less than every 2-4 hours for the first 24 hours) to determine the efficacy of the intervention in reducing pain. If the intervention is ineffective, additional causes of pain should be considered, the plan should then be reevaluated, and appropriate modifications should be made. Pharmacologic interventions should be titrated to achieve optimal pain control with minimal adverse effects. Ongoing reassessment ensures satisfactory pain relief with the most appropriate balance of drug and nondrug strategies.

### Discharge planning

Inpatients, as well as ambulatory surgical patients, should be given a written pain management plan at discharge. Pertinent discharge instructions related to pain management include: specific drugs to be taken; frequency of drug administration; potential side effects of the medication; potential drug interactions; specific precautions to follow when taking the medication (e.g., physical activity limitations, dietary restrictions); and name of the person to notify about pain problems and other postoperative concerns.