# Appendix F

## Contributors

### F1. Acute Pain Management Guideline Panel: Biosketches

- Ada K. Jacox, RN, PhD, FAAN (Panel Co-Chair, 1990 - )
- Independence Foundation Chair in Health Policy
- School of Nursing, Johns Hopkins University

Dr. Jacox is a nurse whose study of pain began in the early 1970s. As co-chair of the pain guideline panel, her responsibilities included oversight of the review of scientific evidence and coordination of the work of the panel, consultants, and staff in the development, testing, and dissemination of the Guideline. She is on the editorial boards of Nursing Administration Quarterly, Nursing Economics, and Annual Review of Nursing Research. Her special interests are in health policy.

- Daniel B. Carr, MD (Panel Co-Chair, 1990 - )
- Director, Division of Pain Management
- Department of Anesthesia, Massachusetts General Hospital

Dr. Carr holds associate professorships in anesthesia and medicine at Harvard Medical School and is a member of the Subcommittee on Quality Assurance of the American Pain Society. In that role, he participated in the development of the American Pain Society's quality assurance standards for pain management. Dr. Carr serves on the editorial board of the Clinical Journal of Pain. In addition to co-directing the work of the panel, Dr. Carr coordinated the interpretation of scientific evidence and assessment of its clinical application. His special interests are stress physiology, analgesic peptides, and burn pain.

- C. Richard Chapman, PhD (1990 - )
- Professor of Anesthesiology
- School of Medicine
- University of Washington

Dr. Chapman is a clinical psychologist who has treated and studied pain since the early 1970s. He is associate director for research at the University of Washington Pain Center; director of the pain and toxicity research program in the Division of Clinical Research, Fred Hutchinson Cancer Research Center; and a director-at-large of the American Pain Society.

- Betty R. Ferrell, PhD, RN, FAAN (1991 - )
- Research Scientist, Nursing Research
- City of Hope Medical Center

Dr. Ferrell is a nurse who treats and studies cancer-related pain. She is an adjunct associate professor in the graduate program at the University of Southern California. Currently, she is a reviewer for the Journal of the American Geriatric Society and the Western Journal for Nursing Research, and she is on the editorial advisory board of the Journal of Pain and Symptom Management. Her special interests are pain in the elderly, quality of life, and quality assurance.

- Howard L. Fields, MD, PhD (1990 - 1991)
- Professor, Departments of Neurology and Physiology
- University of California, San Francisco

Dr. Fields is a consultant neurologist to San Francisco General Hospital and the San Francisco Veterans Administration Hospital and a staff neurologist to the University of California hospitals and clinics. He is the author of one of the most commonly used introductory texts on pain. Dr. Fields is secretary of the International Association for the Study of Pain and on the board of directors of the American Academy of Pain Medicine. He is associate editor for the journal, Pain; on the editorial boards of Brain Research and the Journal of Neuroscience; and on the editorial advisory board of the Journal of Pain and Symptom Management.

- George Heidrich III, RN, MA (1990 - 1991)
- Instructor, Department of Neurology
- University of Wisconsin Medical School
- Clinical Nurse Specialist Affiliate
- University of Wisconsin School of Nursing

During his tenure on the panel, Mr. Heidrich was associate director and director of publications for the World Health Organization Collaborating Center for Symptom Evaluation and a consultant to the Pain Management Team, Center for Health Services, Madison, WI. He is co-editor of the Journal of Pain and Symptom Management, and editor of Cancer Pain Release and publishes a bimonthly column on pain in the American Journal of Nursing.

- Nancy K. Hester, RN, PhD (1990 - )
- Assistant Director, Center for Nursing Research
- Associate Professor, School of Nursing
- University of Colorado Health Sciences Center

Dr. Hester, a nurse, began studying pain in children in 1975. Her research focuses on the child's perception of pain experiences; comforting the child in pain; measurement of procedural, postoperative, and cancer pain in children; and nurse clinical decisionmaking about pain in children. She is a member of the National Center for Nursing Research's panel to set priorities in the study of pain. She is treasurer for the Special Interest Group, Pain in Children, International Association for the Study of Pain. Dr. Hester serves on the editorial boards of the Journal of Pediatric Nursing and Issues in Pediatric Nursing.

- C. Stratton Hill, Jr., MD (1990 - )
- Professor of Medicine
- University of Texas MD Anderson Cancer Center

Dr. Hill has been director of the M.D. Anderson Cancer Center's Pain Service for the past 10 years. He was appointed to the Texas Cancer Council in 1988 and chaired a working group that developed guidelines for cancer pain treatment. He coauthored a bill, The Intractable Pain Treatment Act, and was instrumental in its passage by the 71st Session of the Texas Legislature in July, 1989. Dr. Hill is on the editorial board of the Pain Clinic Journal.

- Arthur G. Lipman, PharmD (1990 - )
- Professor of Clinical Pharmacy
- College of Pharmacy, University of Utah

Dr. Lipman is a clinical pharmacist at the University Hospital Pain Center, University of Utah. While on sabbatical from the University in 1989, he collaborated in developing a cancer pain data system at Sir Michael Sobell House, Churchill Hospital, University of Oxford, England; also during that sabbatical, he was on active duty with the U.S. Public Health Service and provided consultation to the Office of the Chief Pharmacy Officer, Office of the Assistant Surgeon General. Dr. Lipman is editor of the Journal of Pharmaceutical Care in Pain and Symptom Control, and he has served on the editorial board of the American Journal of Hospice Care: The Hospice Journal.

- Charles L. McGarvey III, MS (1990 - )
- Chief, Physical Therapy Service
- Department of Rehabilitation Medicine
- National Institutes of Health

Mr. McGarvey is a physical therapist and a member of the Commissioned Corps of the U.S. Public Health Service. Before coming to the National Institutes of Health in 1983, he was deputy chief of the Physical Therapy Department at the U.S. Public Health Service Hospital in Whiteriver, AZ and before that a staff physical therapist at the U.S. Public Health Service Hospital in Norfolk, VA. He is president of the Oncology Section of the American Physical Therapy Association.

- Christine A. Miaskowski, RN, PhD (1990 - )
- Associate Professor
- Department of Physiological Nursing
- University of California, San Francisco

Dr. Miaskowski is a clinical nurse specialist with extensive experience in the development of standards of practice and their monitoring for quality assurance. From 1988 to 1990, she was Robert Wood Johnson Clinical Nurse Scholar in the Department of Physiological Nursing, University of California, San Francisco; her research focused on mechanisms of opioid-induced analgesia. Prior to that, she was coordinator of clinical practice and quality assurance at Jack D. Weiler Hospital of the Albert Einstein College of Medicine. Dr. Miaskowski is on the board of directors of the Oncology Nursing Society.

- David Stevenson Mulder, MD (1990 - )
- Professor of Surgery, McGill University
- Surgeon-in-Chief, Montreal General Hospital

Dr. Mulder is an academic surgeon with a specialty in cardiothoracic surgery. He has authored, among numerous publications, texts on surgical research and acute life support. In 1989 he was secretary of the International Trauma Society and in 1990, president of the Canadian Association of Clinical Surgeons.

- Richard Payne, MD (1990 - )
- Associate Professor of Neurology
- University of Cincinnati Medical Center

Prior to his current position, Dr. Payne was a long-term member of the Memorial Sloan-Kettering pain treatment group; he has done extensive research on opioid analgesic pharmacology in cancer pain and sickle cell pain. He is a member of the National Cancer Society's National Advisory Committee on the Psychological Aspects of Cancer and the ad hoc Subcommittee on Medical School Courses and Curricula, International Association for the Study of Pain. Dr. Payne is on the editorial board of the Clinical Journal of Pain and has recently coedited a manual on current pain therapies.

- Neil Schechter, MD (1990 - 1991)
- Associate Professor of Pediatrics
- Head, Division of Developmental and Behavioral
- Pediatrics, University of Connecticut, School of Medicine
- Co-Director, Children's Pain Service
- University of Connecticut Health Center

Dr. Schechter is director of the Section of Developmental and Behavioral Pediatrics, St. Francis Hospital and Medical Center, Hartford, CT. His clinical and research experience has focused on the management of procedural pain in children, individual differences in children's responses to pain, and cancer pain in children. He is an editorial advisor for the Journal of Pain and Symptom Management and recently edited a monograph on acute pain in children.

- Barbara S. Shapiro, MD (1991 - )
- Associate Director, Multidisciplinary Pain Management Program
- Children's Hospital of Philadelphia
- Assistant Professor of Pediatrics
- University of Pennsylvania School of Medicine

Dr. Shapiro is a general pediatrician with specialty training in pediatric hematology and oncology. She is a consultant in pediatric pain to the Unit for Experimental Psychiatry, Institute of Pennsylvania Hospital. She participated in the formation of an interdisciplinary pediatric pain service, and the majority of her clinical and research efforts are in the area of pain assessment and management. She is a clinical affiliate in the Department of Anesthesiology at Children's Hospital.

- Robert S. Smith, PhL (1990 - )
- Director, Institute for Medicine
- in Contemporary Society
- State University of New York
- Medical Center at Stony Brook

Father Smith was ordained to the Roman Catholic priesthood in 1958. During the past 10 years, he has taught bioethics in the School of Medicine, State University of New York, Stony Brook, and served on numerous State and national boards dealing with medicine and ethics. He is a member of the New York State Governor's Task Force on Life and Law and the New York State Cardiac Advisory Committee; Fr. Smith is on the board of directors of the United Network for Organ Sharing.

- Carole V. Tsou, MD (1990 - )
- Division of Family Medicine, Center for the Health Sciences
- University of California, Los Angeles

Dr. Tsou is a family physician who has been involved in the education of family physicians at the undergraduate, graduate, and continuing education levels. She recently began a research fellowship in family medicine at the University of California, Los Angeles and formerly was assistant director of the Education Division of the American Academy of Family Physicians.

- Loretta Vecchiarelli, MS (1990 - )
- Rehabilitation Hospital of Western New England

Ms. Vecchiarelli is a rehabilitation counselor and a physician's assistant. She suffered serious burn injuries as a child and subsequently underwent treatment and rehabilitation, which included repeated episodes of treatment-induced pain. She has served as a consumer representative on the panel.

### F2. Acute Pain Management Guideline Peer Reviewers, Consultants, and Contributors

- Robert G. Addison, MD
- Director, Medical Planning
- Rehabilitation Institute of Chicago
- Gerald M. Aronoff, MD
- Director, Boston Pain Center
- Assistant Clinical Professor
- Tufts Medical School
- Charles Berde, MD, PhD
- Director, Pain Treatment Service
- Associate in Anesthesia
- Children's Hospital, Boston
- Associate Professor of Anesthesia
- Harvard Medical School
- Kenneth Blazier, MD
- Department of Anesthesia
- Mercy Hospital, Portland, ME
- Alan Jeffry Breslau
- Executive Director, The Phoenix Society
- for Burn Survivors, Inc., Levittown, PA
- Dorothy Y. Brockopp, RN, PhD
- Clinical Nurse Researcher
- Associate Professor of Nursing
- University of Kentucky
- Marion E. Broome, RN, PhD
- Associate Professor, Assistant
- Chairperson, Maternal-Child Nursing
- Rush-Presbyterian-St. Lukes Medical
- Center, Chicago
- James N. Campbell, MD
- Associate Director,
- Department of Neurosurgery
- Professor of Neurosurgery
- Johns Hopkins Medical School
- Charles Samuel Cleeland, PhD
- Director of World Health Organization
- Collaborating Center for
- Symptom Evaluation
- Director, Pain Research Group
- Professor of Neurology
- University of Wisconsin Medical School
- David E. Cohen, MD
- Director, Pain Management Program
- Department of Anesthesiology
- and Critical Care Medicine
- Assistant Professor of Anesthesia
- University of Pennsylvania
- Judy M. Diekmann, RN, EdD, OCN
- Associate Professor of Nursing
- University of Wisconsin
- Seymour Diamond, MD
- Executive Director
- National Headache Foundation, Chicago
- Marion B. Dolan
- Executive Director & President
- Heritage Home Health & Heritage
- Hospice, Bristol, NH
- Marilee Donovan, RN, PhD
- Associate Hospital Director
- Oregon Health Sciences Center
- JoAnn Eland, RN, PhD, FAAN
- Associate Professor of Nursing
- University of Iowa
- Joyce Marie Engel, OTR, PhD
- Assistant Professor of
- Occupational Therapy
- University of Wisconsin
- Margaret Faut-Callahan,
- CRNA, DNSc, FAAN
- American Association of Nurse
- Anesthetists
- Associate Chairperson
- Operating Room and Surgical Nursing
- Rush-Presbyterian-St. Luke's Medical
- Center, Chicago
- Michael Ferrante, MD
- Director, Pain Treatment Services
- Brigham and Women's Hospital
- Assistant Professor of Anesthesia
- Harvard Medical School
- Roxie Foster, RN, PhD
- Coordinator, Pain Management Service
- The Children's Hospital
- Assistant Research Professor, School of
- Nursing, University of Colorado
- Health Sciences Center
- Rollin M. Gallagher, MD
- Director, The Pain Center
- Stony Brook Health Science Center
- State University of New York
- Randall D. Gaz, MD
- Associate Visiting Surgeon
- Massachusetts General Hospital
- Assistant Professor
- Harvard Medical School
- Stuart A. Grossman, MD
- Director, Neuro-Oncology
- Associate Professor of Oncology
- and Medicine
- Johns Hopkins Oncology Center
- Kenneth M. Hargreaves, DDS, PhD
- Associate Professor of Endodontics
- and Pharmacology
- University of Minnesota
- School of Dentistry
- C. Celeste Johnson, RN, DEd
- Director, Pain Group
- Montreal Children's Hospital
- Associate Professor, McGill University
- Maryalice Jordan-Marsh, RN, PhD
- American Nurses Association
- Director, Nursing Research Division
- Harbor-UCLA Medical Center
- Steven A. King, MD, MS
- Director, Pain Service
- Department of Psychiatry
- Maine Medical Center
- Rev. Jerry L. Loch, CRNA, PhD
- American Association of
- Nurse Anesthetists
- John D. Loeser, MD
- President-Elect, International Association
- for the Study of Pain
- Director and Chief, Pain Service and
- Multidisciplinary Pain Center
- Professor of Neurological Surgery and
- Anesthesia, University of Washington
- Margo McCaffery, RN, MS, FAAN
- Pain Consultant, Los Angeles, CA
- Mitchell Max, MD
- Secretary, American Pain Society
- Clinical Coordinator, Pain Research
- Clinic, National Institute of Dental
- Research, National Institutes of Health
- Ruth McCorkle, RN, PhD
- Professor and Chairperson, Adult Health
- and Illness, University of Pennsylvania
- Patricia A. McGrath, PhD
- Director, Child Health Research Institute
- Associate Professor, Department of
- Pediatrics, Western Ontario University
- Deborah B. McGuire, RN, PhD
- Director of Nursing Research
- Johns Hopkins Oncology Center
- Assistant Professor of Nursing
- Johns Hopkins University
- Paul M. Paris, MD, FACEP
- Associate Professor
- Chief, Division of Emergency Medicine
- University of Pittsburgh
- School of Medicine
- L. Brian Ready, MD, FRCP(C)
- Director, Acute Pain Service
- University of Washington
- Medical Center
- Professor of Anesthesiology
- University of Washington
- Patrick M. Renfro, RN, MS, CRC
- National Rehabilitation Consultants
- Denver, CO
- Linda Jo Rice, MD
- Associate Professor of
- Anesthesiology and Pediatrics,
- Children's National Medical Center
- Catholic University of America
- Anthony J. Richtsmeier, MD
- Director, Section of Behavioral
- Pediatrics, Department of Pediatrics,
- Rush-Presbyterian-St.Luke's Medical
- Center, Chicago
- Marilyn Savedra, RN, PhD, FAAN
- Professor and Acting Chair
- Department of Family Health Care
- Nursing, University of California
- School of Nursing
- Vivian R. Sheidler, MS, RN
- Research Associate and Nursing Clinical
- Specialist, Johns Hopkins Hospital
- George Shorten, MD
- Clinical Research Fellow
- Department of Anesthesia
- Massachusetts General Hospital
- Judith Spross, RN, MS, OCN
- Assistant Professor
- Institute of Health Professions
- Massachusetts General Hospital
- Earl Steinberg, MD, MPH
- Director, Medical Technology and
- Practice Assessment Program,
- Associate Professor of Health Policy
- and Management
- The Johns Hopkins University
- Dennis C. Turk, PhD
- Director, Pain Evaluation and Treatment
- Institute, Center for Sports Medicine
- and Rehabilitation
- Professor of Psychiatry and
- Anesthesiology, University of Pittsburgh
- School of Medicine
- Gail Ulshafer, CRNA
- American Association of Nurse
- Anesthetists, Park Ridge, IL
- Anesthesia Care Associates,
- Yucca Valley, CA
- Sridhar V. Vasudevan, MD
- President-Elect, American Academy
- of Pain Medicine
- Chairman, Department of Physical
- Medicine and Rehabilitation
- St. Joseph's Hospital, Milwaukee, WI
- Andrew L. Warshaw, MD
- Associate Chief of Surgery
- Massachusetts General Hospital
- Harold and Ellen Danser
- Professor of Surgery
- Harvard Medical School
- Steven Woolf, MD
- Consultant, Oakton, VA
- Donald M. Yealy, MD
- Assistant Professor
- Director of Research
- Division of Emergency Medicine
- Texas A & M University Medical Center
- and Scott and White Memorial Hospital
- Lonnie Zeltzer, MD
- Professor of Pediatrics
- Head, Pediatric Pain Program
- UCLA School of Medicine
- J.M. Zimmerman, MD
- Chief of Surgery, Church Hospital
- Associate Professor of Surgery
- The Johns Hopkins University

### F3. Acute Pain Management Guideline Site Review Coordinators

- Jean M. Belt, RN
- Fort Collins Orthopedic Association
- Fort Collins, CO
- Bart Chernow, MD, FACP
- Physician-in-Chief, Sinai Hospital
- of Baltimore; Editor-in-Chief,
- Critical Care Medicine
- Charles Clark, MD
- Chair, Committee on Clinical Policies
- American Academy of
- Orthopedic Surgeons
- Professor, Department of Orthopedic
- Surgery, University of Iowa Hospital
- Clifford W. Colwell, Jr, MD*
- Head, Division of Orthopedic Surgery
- Scripps Clinic
- Kathy Vivenzo Dyble, RN, MSN
- Department of Surgery
- Stanford University Medical Center
- Betty R. Ferrell, RN, PhD, FAAN
- Research Scientist, Department of
- Nursing Research and Education
- City of Hope Medical Center
- Lynda Hall, RNC, PNP, NNP
- Lutheran Medical Center
- Wheat Ridge, CO
- Donald R. Jacobs, MD
- Chairman Pain Management Task Force
- Committee; Medical Director
- Consultation/Liaison Psychiatry
- The Childrens Hospital of Denver
- Maryalice Jordan-Marsh, RN, PhD
- Director, Nursing Research Division
- Assistant Clinical Professor
- Harbor-UCLA Medical Center
- Karen Lindherst, RN
- Emergency Room Nurse Manager
- McKee Medical Center
- Loveland, CO
- Kim Musil, RN, Clinician II
- Poudre Valley Hospital
- Fort Collins, CO
- Rhonda Nichols, RN, MS
- Pain Nurse Clinician
- San Francisco General Hospital
- Larry Owen, CRNA, BSN
- Saint Joseph Hospital
- Lexington, KY
- Patrick Renfro, RN, MS
- Certified Rehabilitation Counselor
- Medical Services Coordinator
- National Rehabilitation Consultants
- Denver, CO
- Thomas P. Sculco, MD*
- Associate Director, New York Hospital
- Associate Professor, Cornell University
- Medical College
- Barry P. Simmons, MD*
- Chief, Hand Surgery Service
- The Brigham & Women's Hospital
- Associate Professor
- Harvard Medical School
- Barbara Tate, RN
- Owner/Operator Case Manager
- Eldercare Homes, Inc., Milliken, CO
- Gail Ulshafer, CRNA, MSN
- American Association of
- Nurse Anesthetists
- Anesthesia Care Associates
- Yucca Valley, CA
- Steven Weisman, MD
- Co-Director, Children's Pain Service
- Associate Professor of Pediatrics
- The University of Connecticut
- Health Center
- Leslie Williams, RN
- St. Anthony Health Care Corporation
- Denver, CO
- Donald M. Yealy, MD
- Assistant Professor
- Director of Research
- Division of Emergency Medicine
- Texas A & M University Medical Center
- and Scott and White Memorial Hospital