# Appendix D

## [Pain Assessment Tools]

D2. Initial Pain Assessment Tool

D2. Initial Pain Assessment Tool

Date _______________________________ Patient's Name ______________________ Age ___________ Room ____________ Diagnosis ____________________________ Physician_________________________ Nurse ____________________________; 1. Location: Patient or nurse indicate site of pain. ____________________ ______________________________________________________________________ ______________________________________________________________________ ______________________________________________________________________ ______________________________________________________________________ ______________________________________________________________________; 2. Intensity: Patient rates the pain. Scale used ________________________ Present: _______________________________________________________ Worst pain gets: _______________________________________________ Best pain gets: ________________________________________________ Acceptable level of pain: ______________________________________; 3. Quality: (Use patient's own words, e.g. prick, ache, burn, throb, pull, sharp ____________________________________ ____________________________________; 4. Onset, duration variations, rhythms: _________________________________ ______________________________________________________________________; 5. Manner of expressing pain: ___________________________________________ ______________________________________________________________________ ______________________________________________________________________; 6. What relieves the pain? ______________________________________________ ______________________________________________________________________ ______________________________________________________________________; 7. What causes or increases the pain? ___________________________________ ______________________________________________________________________ ______________________________________________________________________; 8. Effects of pain: (Note decreased function, decreased quality of life.) Accompanying symptoms (e.g. nausea) ____________________________ Sleep __________________________________________________________ Appetite _______________________________________________________ Physical activity ______________________________________________ Relationship with others (e.g. irratibility) ___________________ Emotions (e.g. anger, suicidal, crying) ________________________ Concentration __________________________________________________ Other __________________________________________________________; 9. Other comments: ______________________________________________________ ______________________________________________________________________; 10. Plan: ________________________________________________________________ ______________________________________________________________________

May be duplicated for use in clinical practice.

Used with permission from McCaffery, M. and Beebe, A. Pain: Clinical Manual for Nursing Practice. (1989). St. Louis: C.V. Mosby.

D3. Flow Sheet -- Pain

D3. Flow Sheet—Pain

Patient ____________________________ Date _______________________________
* Pain rating scale used _________________________________________________
Purpose: to evaluate the safety and effectiveness of the analgesic(s).
Analgesic(s) prescribed: _________________________________________________
Time | Pain Rating | Analgesic | R | P | B | Level of Arousal | Other ** | Plan & Comments