# Appendix C

## Dosage Tables for Adult and Pediatric Patients

C1. Dosing Data for NSAIDs

C1. Dosing Data for NSAIDs

Drug | Usual adult dose | Usual pediatric dose[1] | Comments
Oral NSAIDs
Acetaminophen | 650-975 mg q 4hr | 10-15 mg/kg q 4 hr | Acetaminophen lacks the peripheral anti-inflammatory activity of other NSAIDs.
Asprin | 650-975 mg q 4 hr | 10-15 mg/dg q 4 hr[2] | The standard against which other NSAIDs are compared. Inhibits platelet aggregation; may cause postoperative bleeding.
Choline magnesium trisalicylate (Trilisate) | 1000-1500 mg bid | 25 mg/kg bid | May have minimal anti-platelet activity; also available as oral liquid.
Diflunisal (Dolobid) | 1000 mg initial dose followed by 500 mg q 12 hr
Etodolac (Lodine) | 200-400 mg q 6-8 hr
Fenoprofen calcium (Nalfon) | 200 mg q 4-6 hr
Ibuprofen (Motrin, others) | 400 mg q 4-6 hr | 10 mg/kg q 6-8 hr | Available as several brand names and as generic; also available as oral suspension
Ketoprofen (Orudis) | 25-75 mg q 6-8 hr
Magnesium salicylate | 650 mg q 4 hr | | Many brands and generic forms available
Meclofenamate sodium (Meclomen) | 50 mg q 4-6 hr
Mefenamic acid (Ponstel) | 250 mg q 6 hr
Naproxen (Naprosyn) | 500 mg initial dose followed by 250 mg q 6-8 hr | 5 mg/kg q 12 hr | Also available as oral liquid
Naproxen sodium (Anaprox) | 550 mg initial dose followed by 275 mg q 6-8 hr
Salsalate (Disalcid, others) | 500 mg q 4 hr | | May have minimal anti-platelet activity
Sodium salicylate | 325-650 mg q 3-4 hr | | Available in generic form from several distributors
Parenteral NSAID
Ketorolac tromethamine (Toradol) | 30 or 60 mg IM initial dose followed by 15 or 30 mg q 6 hr Oral dose following IM dosage: 10 mg q 6-8 hr | | Intramuscular dose not to exceed 5 days

Note: Only the above NSAIDs have FDA approval for use as simple analgesics, but clinical experience has been gained with other drugs as well.

C2. Dosing Data for Opioid Analgesics

C2. Dosing Data for Opioid Analgesics

| Approximate equianalgesic | | Recommended starting dose (adults more than 50kg body weight) | | Recommended starting dose (children and adults less than 50kg body weight)[1]
| oral dose | parenteral | oral | parenteral | oral | parenteral
Opioid Agonist Drug
Morphine[2] | 30 mg q 3-4 hr (around-the-clock dosing) | 10 mg q 3-4 hr | 30 mg q 3-4 hr | 10 mg q 3-4 hr | 0.3 mg/kg q 3-4 hr | 0.1 mg/kg q 3-4 hr
Morphine[2] | 60 mg q 3-4 hr (single dose or intermittent dosing)
Codeine[3] | 130 mg q 3-4 hr | 75 mg q 3-4 hr | 60 mg q 3-4 hr | 60 mg q 2 hr (intramulcular/ subcutaneous) | 1 mg/kg 3-4 hr [4] | Not recommended
Hydromophone[2] (Dilaudid) | 7.5 mg q 3-4 hr | 1.5 mg q 3-4 hr | 6 mg q 3-4 hr | 1.5 mg q 3-4 hr | 0.06 mg/kg q 3-4 hr | 0.015 mg/kg q 3-4 hr
Hydrocodone (in Lorcet, Lortab, Vicodin, others) | 30 mg q 3-4 hr | Not available | 10 mg q 3-4 hr | Not available | 0.2 mg/kg q 3-4 hr [4] | Not available
Levorphanol (Levo-Dromoran) | 4 mg q 6-8 hr | 2 mg q 6-8 hr | 4 mg q 6-8 hr | 2 mg q 6-8 hr | 0.04 mg/kg q 6-8 hr | 0.02 mg/kg q 6-8 hr
Meperidine (Demerol) | 300 mg q 2-3 hr | 100 mg q 3 hr | Not recommended | 100 mg q 3 hr | Not recommended | 0.75 mg/kg q 2-3 hr
Methadone (Dolophine,others) | 20 mg q 6-8 hr | 10 mg q 6-8 hr | 20 mg q 6-8 hr | 10 mg q 6-8 hr | 0.2 mg/kq q 3-4 hr [4] | 0.1mk/kg q 6-8 hr
Oxycodone (Roxicodone, also in Percocet, Percodan, Tylox, others) | 30 mg q 3-4 hr | Not available | 10 mg q 3-4 hr | Not available | 0.2 mg/kg q 3-4 hr [4] | Not available
Oxymorphone2 (Numorphan) | Not available | 1 mg q 3-4 hr | Not available | 1 mg q 2-3 hr | Not recommended | Not recommended
Opioid Agonist-Antagonist and Partial Agonist
Buprenorphine (Buprenex) | Not available | 0.3-0.4 mg q 6-8 hr | Not available | 0.4 mg q 6-8 hr | Not available | 0.0004 mg/kg q 6-8 hr
Butorphanol (Stadol) | Not available | 2 mg q 3-4 hr | Not available | 2 mg q 3-4 hr | Not available | Not recommended
Nalbuphine (Nubain) | Not available | 10 mg q 3-4 hr | Not available | 10 mg q 3-4 hr | Not available | 0.1 mg/kg q 3-4 hr
Pentazocine (Talwin, others) | 150 mg q 3-4 hr | 60 mg q 3-4 hr | 50 mg q 4-6 hr | Not recommended | Not recommended | Not recommended