# Appendix B

## Summary Table of Scientific Evidence for Interventions to Manage Pain in Adults

B1. Pharmacologic Interventions

B1. Pharmacologic Interventions

Intervention [1] | | Type of Evidence [2] | Comments
NSAIDs | Oral (alone) | Ib, IV | Effective for mild to moderate pain. Begin preoperatively. Relatively contraindicated in patients with renal disease and risk of or actual coagulopathy. May mask fever.
NSAIDs | Oral (adjunct to opioid) | Ia, IV | Potentiating effect resulting in opioid sparing. Begin pre-op. Cautions as above.
NSAIDs | Parenteral (ketorolac) | Ib, IV | Effective for moderate to severe pain. Expensive. Useful where opioids contraindicated, especially to avoid respiratory depression and sedation. Advance to opioid.
Opioids | Oral | IV | As effective as parenteral in appropriate doses. Use as soon as oral medication tolerated. Route of choice.
Opioids | Intramuscular | Ib, IV | Has been the standard parenteral route, but injections painful and absorption unreliable. Hence, avoid this route when possible.
Opioids | Subcutaneous | Ib, IV | Preferable to intramuscular when a low-volume continuous infusion is needed and intravenous access is difficult to maintain. Injections painful and absorption unreliable. Avoid this route for long-term repetitive dosing.
Opioids | Intravenous | Ib, IV | Parenteral route of choice after major surgery. Suitable for titrated bolus or continuous administration (including PCA), but requires monitoring. Significant risk of respiratory depression with inappropriate dosing.
Opioids | PCA (systemic) | Ia, IV | Intravenous or subcutaneous routes recommended. Good steady level of analgesia. Popular with patients but requires special infusion pumps and staff education. See cautions about opioids above.
Opioids | Epidural & intrathecal | Ia, IV | When suitable, intrathecal provides good analgesia. Significant risk of respiratory depression, sometimes delayed in onset. Requires careful monitoring. Use of infusion pumps requires additional equipment and staff education. Expensive if infusion pumps are employed.
Local anesthetics | Epidural & intrathecal | Ia, IV | Limited indications. Effective regional analgesia. Opioid sparing. Addition of opioid to local anesthetic may improve analgesia. Risks of hypotension, weakness, numbness. Requires careful monitoring. Use of infusion pump requires additional equipment and staff education.
Local anesthetics | Peripheral nerve block | Ia, IV | Limited indications and duration of action. Effective regional analgesia. Opioid sparing.

[1] Selected references are included in this Clinical Practice Guideline. More complete references are available; see Acute Pain Management Guideline Panel. Acute Pain Management: Operative or Medical Procedures and Trauma. Guideline Report. AHCPR Pub. No. 92-0022. Rockville, MD: Agency for Health Care Policy and Research, Public Health Service, U.S. Department of Health and Human Services. In press.

[2] See type of evidence key following B2, page 107.

B2. Nonpharmacologic Interventions

B2. Nonpharmacologic Interventions

Intervention [1] | | Type of Evidence [2] | Comments
Simple relaxation (begin preoperatively) | Jaw relaxation Progressive muscle relaxation Simple imagery | Ia, IIa, IIb, IV | Effective in reducing mild to moderate pain and as an adjunct to analgesic drugs for severe pain. Use when patients express an interest in relaxation. Requires 3-5 minutes of staff time for instructions.
Simple relaxation (begin preoperatively) | Music | Ib, IIa, IV | Both patient-preferred and "easy listening" music are effective in reducing mild to moderate pain.
Complex relaxation (begin preoperatively) | Biofeedback | Ib, IIa, IIb, IV | Effective in reducing mild to moderate pain and operative site muscle tension. Requires skilled personnel and special equipment.
Complex relaxation (begin preoperatively) | Imagery | Ib, IIa, IV | Effective for reduction of mild to moderate pain. Requires skilled personnel.
Education/instruction (begin preoperatively) | | Ia, IIa, IIb, IV | Effective for reduction of pain. Should include sensory and procedural information and instruction aimed at reducing activity related pain. Requires 5-15 minutes of staff time.
- TENS | | Ia, IIa, III, IV | Effective in reducing pain and improving physical function. Requires skilled personnel and special equipment. May be useful as an adjunct to drug therapy.

[1] Selected references are included in this Clinical Practice Guideline. For more complete references, see: Acute Pain Management Guideline Panel. Acute Pain Management: Operative or Medical Procedures and Trauma. Guideline Report. AHCPR Pub. No. 92- 0022. Rockville, MD: Agency for Health Care Policy and Research, Public Health Service, U.S. Department of Health and Human Services. In press.

[2] Insufficient scientific evidence is available to provide specific recommendations regarding the use of hypnosis, acupuncture, and other physical modalities for relief of postoperative pain.

Type of Evidence -- Key

Type of Evidence—Key

Ia | Evidence obtained from meta-analysis of randomized controlled trials.
b | Evidence obtained from at least one randomized controlled trial.
IIa | Evidence obtained from at least one well-designed controlled study without randomization.
b | Evidence obtained from at least one other type of well-designed quasi-experimental study.
III | Evidence obtained from well-designed nonexperimental studies, such as comparative studies, correlational studies, and case studies.
IV | Evidence obtained from expert committee reports or opinions and/or clinical experiences of respected authorities.