# How Does Mentoring Impact Diversity in the Biomedical and Behavioral Research Workforce?

## 1 Executive Summary

This document encapsulates the proceedings of “How Does Mentoring Impact Diversity in the Biomedical and Behavioral Research Workforce? (https://diversity.nih.gov/disseminate/swd-seminar-series/how-does-mentoring-impact-diversity-biomedical-and-behavioral),” the fourth and final seminar of the 2022–2023 Scientific Workforce Diversity Seminar Series (https://diversity.nih.gov/disseminate/swd-seminar-series) (SWDSS). The National Institutes of Health (NIH) Chief Officer for Scientific Workforce Diversity (https://diversity.nih.gov/) (COSWD) office hosted the seminar on June 14, 2023. Marie A. Bernard, M.D., COSWD, moderated a panel discussion on how successful mentoring relationships can positively impact the career trajectory of biomedical and behavioral researchers across the talent cycle. Panelists focused on why these relationships are particularly important for attracting and retaining diverse talent, including from underrepresented groups.

This document summarizes the main points from the speakers’ presentations and the subsequent question-and-answer session. The seminar recording (https://videocast.nih.gov/watch=49766) and panelists’ presentation materials (https://diversity.nih.gov/disseminate/swd-seminar-series/how-does-mentoring-impact-diversity-biomedical-and-behavioral) are on the COSWD website.

The seminar featured the following panelists:

- [image]Angela Bvars-Winston, Ph.D. (https://www.medicine.wisc.edu/people-search/people/staff/1094/Byars-Winston_Angela), Professor, Division of General Internal Medicine, Department of Medicine, University of Wisconsin-Madison
- [image]Jessie DeAro. Ph.D. (https://www.nsf.gov/staff/staff_bio.jsp?lan=jdearo&from_org=NSF), Lead Program Director, ADVANCE, National Science Foundation
- [image]Christine Pfund, Ph.D. (https://www.wcer.wisc.edu/About/Staff/996), Distinguished Senior Scientist, Wisconsin Center for Education Research, Institute for Clinical and Translational Research, University of Wisconsin–Madison
- [image]Juan Amador, FASAE, CAE (https://www.sacnas.org/diversity-news/announcing-sacnas-executive-director), Executive Director, Society for Advancement of Chicanos/Hispanics & Native Americans in Science
- [image]Karen N. Salt. Ph.D. (https://metascience2021.org/speakers/salt/), Deputy Director for Research Culture and Environment, UK Research and Innovation

## 2 Opening Remarks

Marie A. Bernard, M.D., NIH COSWD

Dr. Bernard welcomed attendees to the final seminar in the 2022–2023 SWDSS season. The seminar focused on the role of mentorship in training researchers, including those from underrepresented groups in science. Dr. Bernard polled attendees regarding the role of mentorship in their careers, both as mentor and mentee. Responses included the following:

- When asked about support received from mentors during their careers, 38% of respondents reported three to five, 33% reported more than five, 26% reported one to two, and 4% reported none.
- When asked about preferences for discussing personal and professional issues with a mentor, most respondents (79%) reported preferring mentors who were open to discussing both personal and professional topics rather than only professional topics.
- When asked about the importance of a mentor and mentee being from the same race or ethnicity, respondents expressed varied views: 35% responded “neutral,” 25% responded “not important,” 28% responded “somewhat important,” and 14% responded “very important.”
- When asked whether they had served as mentors themselves, most respondents (81%) confirmed that they had.
- When asked what excited them most about being a mentor, 46% responded “paying it forward to the next generation,” 36% responded “learning about another person’s perspective and developing relationships,” and 19% responded “sharing my wisdom to help others.”

Dr. Bernard noted that the topic of mentorship and shared backgrounds between mentors and mentees would be an important part of the seminar discussion.

## 3 Science of Effective Mentorship: What’s Cultural Diversity Got To Do With It?

Angela Byars-Winston, Ph.D., Professor, Division of General Internal Medicine, Department of Medicine, University of Wisconsin–Madison

Dr. Byars-Winston began her presentation by reviewing the 2019 National Academies of Sciences, Engineering, and Medicine (NASEM) report The Science of Effective Mentorship in STEMM,^1^ written by a committee she chaired. Based on the science and practice of mentoring in science, technology, engineering, mathematics, and academic medicine (STEMM), the NASEM report defines mentorship as “a professional, working alliance in which individuals work together over time to support the personal and professional growth, development, and success of the relational partners through the provision of career and psychosocial support.” The report uses the term “mentorship” rather than “mentoring” to reflect how both the mentor and mentee shape and benefit from the relationship.

Dr. Byars-Winston focused on three points among many contained in the report:

- Mentorship occurs within a “mentorship ecosystem” of individual, institutional, inter-institutional, societal, and cultural contexts, and these larger contexts shape mentorship expectations and experiences.
- Mentorship is a learned skill. Despite the importance of mentorship, NASEM found that only 7% of higher education faculty surveyed had received formal mentorship education.^1^
- Recognizing and responding to a mentee’s cultural and social identities contributes to mentoring effectiveness. Culturally responsive mentorship, in which mentors show interest in and value mentees’ cultural backgrounds and social identities, is a learned skill set that positively correlates with satisfaction with the mentoring relationship, commitment to a research career,^2^ pursuit of graduate education, and research career entry.^3^

These three points emphasize the importance of inclusion in ensuring and enhancing scientific workforce diversity. Inclusion is crucial for avoiding the “diversity disconnect”; that is, when institutions focus on enhancing diversity without addressing the systemic diversity issues within science.^4^

Dr. Byars-Winston described two recent intervention studies she coauthored on the importance of culturally responsive mentorship in the sciences. The first study^5^ conducted a randomized control trial of the Entering Mentoring curriculum with and without (control condition) an enhanced cultural awareness (ECA) module for mentors of undergraduate students. Although both trainings had positive effects on mentors, relative to the control group, mentors who received the ECA module were more likely to endorse the statement, “My racial/ethnic identity is relevant to my research mentoring relationships.” Similarly, mentees paired with mentors who received the ECA module rated their mentors higher on respectfully broaching and creating opportunities to raise issues related to race and ethnicity.^5^

The second study, conducted at the University of California San Diego Health, was a two-day workshop that emphasized culturally inclusive faculty mentorship. The researchers found that workshop participation improved mentors’ perceptions of meeting mentees’ expectations and improved morale and perceived support among mentees from underrepresented groups.^6^

## 4 National Science Foundation ADVANCE Systemic Change in Support of Effective Mentoring

Jessie DeAro, Ph.D., Lead Program Director, ADVANCE, National Science Foundation

Dr. DeAro described three common problems with scientific mentoring that frequently hinder efforts to enhance diversity and inclusion:

- Mentoring programs do not produce systemic change. However, creating a culture of caring and mentoring within an institution can lead to larger systemic changes.
- Not all scientific and academic professionals are skilled mentors. Training and support can improve some professionals’ mentoring skills, but a systemic solution could require hiring and promoting based on mentorship skills.
- Some mentoring programs are “Band-Aid solutions” that help some people in STEMM fields survive. Concurrent organizational changes to increase inclusion and accessibility are required for everyone to thrive.

Dr. DeAro highlighted the National Science Foundation (NSF) ADVANCE program (https://new.nsf.gov/funding/opportunities/advance-organizational-change-gender-equity-stem), which aims to increase the representation and advancement of women faculty in STEMM, as an example of a program creating broad-based systemic change. ADVANCE employs six institutional factors that support effective faculty mentoring:

1. Formal mentoring programs for all faculty rather than for specific subgroups.
2. Clear, consistent, and transparent policies and procedures for faculty evaluation, promotion, and tenure.
3. Tailored mentoring based on the mentee’s career stage (e.g., early vs. late career).
4. Recognition of mentorship time and effort during faculty evaluation, promotion, and tenure decisions.
5. Evidence-based training, support, and resources for faculty mentors.
6. Multiple points of mentoring contact (e.g., group mentoring) for faculty and processes for resolving poor matches between mentors and mentees.

An overview of ADVANCE systemic change strategies, including mentoring models, is available in the StratEGIC toolkit (https://www.colorado.edu/eer/research-areas/women-science/strategic-toolkit). Resources developed by past ADVANCE grantees and others doing work on gender equity in STEMM are available in the ADVANCE Resource Coordination (ARC) Network’s resource library (https://www.equityinstem.org/resource-library). ARC Network membership and access to the resources are open to the public.

Dr. DeAro described the Launch Committees at the University of Michigan as an example of a successful ADVANCE intervention. A Launch Committee consists of four mentors who provide a junior faculty mentee with structured support and guidance: the department chair, a senior faculty member within the department with similar research interests to the mentee, a senior faculty member from outside the department, and a trained committee convener. According to annual program evaluations, the program eliminated gender, race, and ethnicity differences in satisfaction with teaching load, courses assigned, mentorship, and their department being a good place for junior faculty.^7^ However, gender differences remained in how well the new faculty members felt they were integrated into the department.

Dr. DeAro closed with an overview of the three types of systemic change grants that ADVANCE offers to enhance academic work environments:

- Catalyst grants enable institutions of higher education (IHEs) to perform institutional assessments, pilot potential organizational change strategies, and develop five-year STEMM faculty equity plans.
- Adaptation grants enable IHEs to adapt proven systemic change strategies to enhance gender equity for STEMM faculty within an institution.
- Institutional Transformation grants support the implementation of systemic change strategies as well as develop, implement, and conduct original research on innovative organizational strategies to enhance gender equity for STEMM faculty.

## 5 Mentorship as a Mechanism To Advance Inclusive Environments

Christine Pfund, Ph.D., Distinguished Senior Scientist, Wisconsin Center for Education Research, University of Wisconsin–Madison

Dr. Pfund highlighted mentorship as one of many interventions that can enhance diversity and retention in STEMM disciplines. Institutional transformation that supports effective mentorship involves mentors, mentees, training program directors, deans, departmental chairs, college presidents, and external stakeholders. These individuals can all use mentorship as one of numerous interventions to enhance retention in STEMM.^1^

Dr. Pfund noted that individuals, organizations, and institutions can support effective mentorship by focusing on the following four areas:

### Access

Mentees must have access to mentors to meet their varied needs. Research demonstrates the importance of transitioning mentorship from occurring only in dyads (i.e., single mentor and mentee) to a mentoring network that includes multiple mentors and training resources.^1,8^ An example of one program aimed at helping mentees expand their mentor networking is the NIH-supported National Research Mentoring Network (NRMN) Resource Center (https://nrmnet.net/). It hosts a mentorship platform that allows mentees to find mentors and access group mentoring.

### Quality

Formal mentorship education for mentors and mentees influences mentorship relationships and research experiences, improving mentorship effectiveness and career outcomes.^5^ For example, the Center for the Improvement of Mentored Experiences in Research (https://cimerproject.org/) is a national training hub for mentorship education. It provides free training curricula, as well as mentor, mentee, train-the-trainer, and implementation training and services.

### Continuous Improvement

Effective mentorship programs use a scientific approach^9^ to monitor various evidence-based mentorship measures (e.g., relational duration and quality, interaction frequency) to assess program impact and identify areas for improvement. Dr. Pfund noted that the Wisconsin Center for Education Research hosts an NIH-supported pilot library of measures (https://projects.wcer.wisc.edu/materials-library/) for evaluating mentorship quality.

### Value and Visibility

Visibly demonstrating an organization’s commitment to inclusive mentorship can improve mentoring outcomes. Potential approaches for demonstrating the value of mentorship include adding mentorship goals to strategic plans, building mentorship into regular workloads, and evaluating mentorship efforts in tenure and promotion decisions.^10^

## 6 Juan Amador, FASAE, CAE, Executive Director, Society for Advancement of Chicanos/Hispanics & Native Americans in Science

In his role as reactant, Mr. Amador began by highlighting key points from the three presentations on mentorship. These points were the importance of culturally responsive mentoring, the need for systemic change to enhance inclusion in addition to diversity, and systematic and evidence-based approaches for improving mentorship.

Mr. Amador then explained that the Society for Advancement of Chicanos/Hispanics & Native Americans in Science (https://www.sacnas.org/) (SACNAS) focuses on enhancing the mentorship ecosystem to advance the participation of underrepresented groups in science, particularly Chicanos/Hispanics and Native Americans. SACNAS offers four types of programs to assist its members:

- Professional programs, such as the SACNAS Postdoc Cohort Program and the NSF and SACNAS Grant Writing and Peer Review Workshop.
- Leadership programs, such as the Linton-Poodry SACNAS Leadership Institute and SACNAS Postdoc Leadership Institute.
- Programs for Native Americans, such as the virtual SACNAS community for Tribal Colleges and Universities (TCU), TCU mini-conferences, and Scholars in Science: Native American Pathway.
- Mentoring opportunities, such as the Mentor Activation for Students Program, research programs, and SACNAS CareerCon.

SACNAS collaborates with organizations and federal agencies such as NIH and NSF to leverage their resources and mentorship opportunities. SACNAS is also developing a more formal mentorship curriculum and improving its communications (e.g., webinars, publications). Through these initiatives, SACNAS aims to communicate mentee stories and the importance of culturally responsive mentorship more effectively within communities.

## 7 Karen N. Salt, Ph.D., Deputy Director for Research Culture and Environment, UK Research and Innovation

In her role as reactant, Dr. Salt began by emphasizing the importance of culturally responsive mentoring. She noted the influence of power dynamics within mentoring relationships, including how institutional and structural factors might amplify these dynamics. To address power dynamics, institutions in the United Kingdom are increasingly interested in “reverse mentoring”; that is, when a member of an underrepresented group mentors someone outside that group.

Dr. Salt highlighted the role of repair within mentoring relationships, which refers to trust building and considers the structural inequalities, disadvantages, and systemic structural barriers mentees experience. Integrating the role of repair into mentorship networks and relationships requires reflection on the impacts of these dynamics on mentees and their career progression.

Dr. Salt agreed with the need for continuous improvement within mentorship programs and what that means. Improvement should account for how mentoring evolves over time and in different contexts. As such, mentorship approaches might be customized to consider career stages, individual circumstances, and changes in larger systems.

Dr. Salt concluded her remarks by highlighting the importance of career strategists who can provide input on research directions or career decisions. Strategists would play a role distinct from coaches and mentors and assist with evaluating research and career decisions.

## 8 Question-and-Answer Session

Q. What is the quality of existing data regarding the impact of mentorship on diversity, equity, and inclusion within the scientific workforce? How might we improve our analysis of mentor effectiveness?

Dr. Byars-Winston: First, we need validated ways to measure diversity-, equity-, and inclusion-related outcomes.^11^ Second, to capture the effect of mentorship interventions, we must track mentee outcomes over the long term.

Dr. DeAro: We should also investigate how mentorship impacts the mentor as well as the mentee.

Dr. Pfund: I will add two points. Evidence regarding the impacts of mentorship is encouraging, but there is a lot of work to do. For many years, we did not have standardized language to discuss mentorship. The next decade of work will be grounded in common terminology. Mentorship contributes to diversity, equity, and inclusion, but it is only one of many factors and needs to be studied within the broader context in which it occurs.

Mr. Amador: Many qualities in mentorship relationships are difficult to quantify. How should we measure the nature of how mentees and mentors show up for each other? What methods could we develop or implement to measure these characteristics, whether from qualitative or quantitative data?

Dr. Salt: I advise caution when interpreting mentorship effectiveness. We struggle to disentangle the effect of mentorship from a swath of other interventions that often are implemented simultaneously. We must be able to methodically test mentorship as an intervention to determine its effectiveness. I also want to reaffirm Mr. Amador’s point that mentoring relationships are difficult to quantify. For example, when we ask about an individual’s socioeconomic status (SES), are we referring to their experience growing up or their current status? Are we asking about their current debt burden? Are we asking how the cost-of-living crisis affects them? These dimensions of SES are relevant, but we must ask ourselves whether we can reasonably assess these dimensions in a respectful way.

Q. Many mentors hear “culturally responsive” and assume we are only talking about race and ethnicity. What strategies might help capture dimensions of diversity often treated as mere traits to be mitigated (e.g., disability, SES, educational attainment)?

Dr. Salt: The people implementing mentorship interventions ought to approach the task with an open mind. They should encourage people to bring their whole selves. Do not search for people on the internet and then make presumptions about their perspectives based on what they visibly represent. Additionally, rather than judging candidates by their publication list, we should ask about their personal narrative.

Mr. Amador: We must always approach tasks with cultural humility. That may mean we must adapt mentorship programs to meet the needs of individual mentees. When I began attending the Association of American Indian Physicians meetings, I thought just being there was enough. I participated for three years before I gained their trust. We must learn about the mentees’ culture and consider how best to respond to their needs. We must not map our needs as an organization onto them.

Dr. Pfund: We should investigate what people think when they hear “culturally responsive” and why. If race and ethnicity come to mind first, we should ask why that is the case.

Dr. DeAro: We may try to reframe this. Florida A&M University, a historically Black university, is training faculty to use cultural humility as a framework to learn about gender and race. They aim to teach faculty that there is not one way to look, do, or be.

Dr. Byars-Winston: I encourage our listeners to read the research on cultural humility by Joshua Hook and Jesse Owen.^12^ They find that cultural humility has three components.^13^ One of these components involves looking for the opportunity to focus on cultural diversity. Regardless of the dimension of human diversity we want to describe, we must maintain an “other-focused” orientation rather than a “self-focused” orientation. Our team focuses on race and ethnicity because they are the things that most people are least comfortable talking about. We found that when people become comfortable talking about race and ethnicity, they are more likely to discuss other dimensions of the human experience, like LGBTQ+ status, disabilities, et cetera.

Q. Dr. Byars-Winston, you discuss mentorship as a high-stakes, high-impact endeavor, but these stakes are not often discussed. Could you elaborate on these stakes and risks?

Dr. Byars-Winston: I will highlight work from my colleagues that illustrates what happens when mentorship is implemented well versus when it is not. NASEM published the report, Graduate STEM Education for the 21st Century,^14^ which highlighted that mentorship is not the only factor that determines a trainee’s success, but it is a significant factor. It is also important to acknowledge that many trainees persist despite ineffective mentors.

Q. Dr. DeAro, how effective are mentoring programs for nontenured faculty, who represent roughly 75% of all faculty and who are often members of underrepresented racial groups?

Dr. DeAro: Mentorship is just as important for these faculty. But the challenge is, if there are no institutional career pathways for the nontenured track faculty, that faculty do not have a clear path to success and thus may not reap the benefits of mentorship to the same degree. Some institutions have created career pathways for their nontenured track faculty that allow for parallel advancement and job security. We must enact systemic changes that allow faculty to transition from nontenured to tenured positions.

Dr. Salt: I would like to add that in the UK, we no longer have tenure in the same way the U.S. does. Despite this, we still have some of the same pressures of finding roles and a proliferation of people in short-term contracts. In the UK, we have the Technicians Commitment, which recognizes the contributions of people who are not on a tenure track. I would also like to emphasize that a range of individuals are part of the research infrastructure but are often overlooked. These individuals include research administrators, lab technicians, plant operators, security staff, health and safety officers, et cetera. We would collapse without the infrastructure these individuals provide, and we must consider their career paths going forward.

Q. Having many mentors can lead to widely differing advice. Dr. Pfund, how do mentees integrate this differing advice?

Dr. Pfund: Although group/team mentoring has enormous potential to benefit mentees, they must navigate a complex system of support. This can be challenging. Not having mentors coordinated puts a tremendous responsibility on the mentee to navigate a complex network. Mentorship education in navigating multiple mentors, navigating mentor networks, and helping mentors understand the complexity of their networks can help mitigate things like conflicting advice. We have been piloting some co-mentorship interventions. This is an exciting area of mentorship education intervention research.

Mr. Amador: Faculty mentees benefit when their mentors occupy varying positions (professor, department chair, researcher, clinical workers, writers) because these mentors provide different skills. The institution should ask itself, “Are we facilitating diverse relationships that meet mentee needs?”

Q: Can you each provide a quick takeaway from this session?

Dr. Pfund: Seeing the large number of people interested in the science and practice of mentorship makes me excited about the future and how mentorship will support inclusive excellence.

Mr. Amador: We need more partnerships. If we solidify more partnerships, we can make a greater impact.

Dr. Salt: If we want mentorship to lead to action, we need to be clear about the intention of the mentorship (e.g., sharing information, providing a letter of recommendation).

Dr. DeAro: With systemic change, we may move from mentorship to sponsorship through providing letters of recommendation and introductions.

Dr. Byars-Winston: If we want something different, we must do something different. We must make a plan to advance culturally responsive mentorship.

## Supplemental materials

Dr. Amador’s slides

Dr. Byars-Winston’s slides

Dr. DeAro’s slides

Dr. Pfund’s slides

Video Recording

## References

1 National Academies of Sciences, Engineering, and Medicine; Policy and Global Affairs; Board on Higher Education and Workforce; Committee on Effective Mentoring in STEMM, Dahlberg ML, Byars-Winston A, eds. The Science of Effective Mentorship in STEMM. Washington, DC: National Academies Press; 2019.
2 Haeger H, Fresquez C. Mentoring for inclusion: The impact of mentoring on undergraduate researchers in the sciences. CBE Life Sci Educ. 2016;15(3):ar36.
3 Zorec K. “We’re all for the same mission”: Faculty mentoring Native Hawaiian undergraduates in STEM research. J Divers High Educ. 2022.
4 Puritty C, Strickland LR, Alia E, Without inclusion, diversity initiatives may not be enough. Science. 2017;357(6356):1101–1102.28912234
5 Byars-Winston A, Rogers JG, Thayer-Hart N, Black S, Branchaw J, Pfund C. A randomized controlled trial of an intervention to increase cultural diversity awareness of research mentors of undergraduate students. Sci Adv. 2023;9(21):eadf9705.37224257
6 Trejo J, Wingard D, Hazen V, A system-wide health sciences faculty mentor training program is associated with improved effective mentoring and institutional climate. J Clin Transl Sci. 2021;6(1):e18.35291213
7 Stewart AJ, Malley JE, Linderman JL. Launching new faculty careers: Building a strong foundation for a diverse faculty. J Women Minor Sci Eng. 2021;27(1):85–106.
8 Deanna R, Merkle BG, Chun KP, Community voices: The importance of diverse networks in academic mentoring. Nat Commun. 2022;13(1):1681.35338138
9 Montgomery BL, Sancheznieto F, Dahlberg ML. Academic mentorship needs a more scientific approach. Issues Sci Technol. 2022;38(4):84–87.
10 Morrison JA, Barthell JF, Boettcher A, Recognizing and valuing the mentoring of undergraduate research, scholarship, and creative activity by faculty members: Workload, tenure, promotion, and award systems. CUR White Paper No. 2. Online Submission. 2019.
11 Byars-Winston A, Butz AR. Measuring research mentors’ cultural diversity awareness for race/ethnicity in STEM: Validity evidence for a new scale. CBE Life Sci Educ. 2021;20(2).
12 Hook JN, Davis DE, Owen J, Worthington EL, Utsey SO. Cultural humility: Measuring openness to culturally diverse clients. J Couns Psychol. 2013 Jul;60(3):353–366.23647387
13 Watkins CE Jr, Hook JN, Owen J, DeBlaere C, Davis DE, Van Tongeren DR. Multicultural orientation in psychotherapy supervision: Cultural humility, cultural comfort, and cultural opportunities. Am J Psychother. 2019;72(2):38–46.30945559
14 National Academies of Sciences, Engineering, and Medicine. Graduate STEM Education for the 21st Century. Washington, DC: The National Academies Press; 2018.