# Tutorial list

The following list of Coffee Breaks is organized according to the NCBI bioinformatics resource featured in the tutorial that accompanies the story.

## BLAST (Basic Local Alignment Search Tool)

A gut feeling: bugs are critical for good healthJuly 24, 2013

## ClinVar

Turning the white fat brown: a new approach to obesity?March 3, 2014

## Genetic Testing Registry

DNAs of our lives: the role of pharmacogenomics in modern medicineApril 25, 2013

## GEO (Gene Expression Omnibus)

Do brains have a freshness date? the effect of aging on the human brainJanuary 12, 2005

## NIH Clinical Research Trials

How low can you go? the promise of a new class of cholesterol lowering drugsMarch 25, 2014

## Structure and Cn3D

Yoda and the fountain of youth? the many hats of IGF-1July 21, 2014

Variations on a gene: investigating the causes of iron overloadAugust 25, 2003

## dbSNP (Database of Single Nucleotide Polymorphisms)

Roses, noses, and underarms: how one variation in our DNA influences underarm perspiration (and ear wax) March 25, 2013

## PopSet (Population Sets)

What you see is not what you get! DNA barcoding is helping scientists unveil nature's most hidden diversityAugust 06, 2005