# PTEN and the tumor suppressor balancing act

PTEN turns out to be the first tumor suppressor to have phosphatase activity

Tumors are formed by an abnormal proliferation of undifferentiated cells. At the molecular level, this represents a failure to adequately control cell growth and division.

In normal cells, there are many genes that code for regulatory proteins, which are responsible for maintaining the delicate balance required for cell division to proceed at the right time and in the right place. Among these, proto-oncogenes stimulate the cell division cycle, whereas tumor suppressor genes act as brakes. When these types of genes fail to do their jobs, perhaps as a result of a mutation, the control mechanisms break down and cancerous growth can ensue.

The PTEN tumor suppressor gene acts as a phospholipid phosphatase

(A) Under normal growth conditions, stimulatory signals from the insulin receptor activate the enzyme phosphoinositide kinase (PI3-kinase), which phosphorylates phosphatidylinositol 4,5-bisphosphate (PIP2) to generate phosphatidylinositol 3,4,5-trisphosphate (PIP3), a lipid signaling molecule. Downstream, PIP3 activates several effectors, including the proto-oncogene product PKB/Akt. The role of PTEN is to dephosphorylate PIP3, acting as a negative control on PKB/Akt activation.

(B) If a mutation in PTEN renders it unable to carry out its phosphatase function, PIP3 can no longer be deactivated, so continues to propagate its signal downstream. This may result in the continued activation of PKB/Akt , which, in combination with other factors, could lead to increased cell growth and possible tumor development.

Because many proto-oncogenes are kinases (enzymes that have a stimulatory effect in cell signaling pathways), the existence of a tumor suppressor gene that acts as a phosphatase (an enzyme that counteracts the action of kinases) was predicted. However, it was almost 10 years after the discovery of the retinoblastoma gene, the first tumor suppressor to be described, that a gene product answering to this phosphatase description was found.

The PTEN gene, located on chromosome 10q23, is missing or mutated in a variety of human cancers, including glioblastoma (a type of brain cancer), endometrial (uterine) tumors, and prostate cancer, as well as in Cowden disease cells. PTEN stands for "phosphatase and tensin homolog". As well as having phosphatase activity, PTEN is similar to tensin, a protein that interacts with actin filaments at sites of intense signaling activity on the inner surface of cells known as focal adhesions.

PTEN taken from tumors often has a disabling mutation in the phosphatase domain, showing that it is important for normal PTEN function. But what might PTEN's substrate be? Although PTEN can act on both proteins and lipids in vitro, its favorite physiological substrate appears to be phosphatidylinositol 3,4,5-trisphosphate (PIP3), a lipid signaling molecule.

PIP3 is generated by the enzyme phosphoinositide kinase (PI3-kinase), which itself is activated by stimulatory signals emanating from the cell surface, often from focal adhesions. PIP3 activates yet another kinase called PKB/Akt, a proto-oncogene product. If PTEN fails to deactivate PIP3 because of a mutation in its phosphatase domain, downstream signals are not switched off, and therefore PKB/Akt remains in the "on" state. In this case, PKB/Akt can continue to stimulate downstream proteins such as transcription factors and glucose transporters, which could lead to enhanced cell growth.

PTEN is not exclusively a human protein. In the worm Caenorhabditis elegans, a PTEN homolog seems to help control lifespan and dauer formation (a hibernation state). Use of such animal models will help further investigate PTEN and could give clues to outstanding questions, such as how PTEN itself is regulated.

Search PubMed for the function of tensin

Created: November 10, 1999

Click on the link below to start an html tutorial.

What does tensin do?

Use BLAST to search for proteins similar to PTEN

Created: November 10, 1999

Click on the link below to start an html tutorial.

Search for proteins similar to PTEN

## Live PubMed searches

(1) PTEN in Cowden disease

(2) The PTEN lipid phosphatase

(3) REVIEWS

## Additional NCBI resources

NCBI Map Viewer (http://www.ncbi.nlm.nih.gov/projects/mapview/map_search.cgi?taxid=9606&query=PTEN&qchr=&strain=All)

Entrez Gene

OMIM