# Appendix E Two-Letter Abbreviations for Canadian Provinces and Territories and U.S. States and Territories

Canadian Provinces and Territories | Two-Letter Abbreviation
Alberta | AB
British Columbia | BC
Manitoba | MB
New Brunswick | NB
Newfoundland and Labrador | NL
Northwest Territories | NT
Nova Scotia | NS
Nunavut | NU
Ontario | ON
Prince Edward Island | PE
Quebec | QC
Saskatchewan | SK
Yukon | YT

U.S. States and Territories | Two-Letter Abbreviation
Alabama | AL
Alaska | AK
American Samoa | AS
Arizona | AZ
Arkansas | AR
California | CA
Colorado | CO
Connecticut | CT
Delaware | DE
District of Columbia | DC
Federated States of Micronesia | FM
Florida | FL
Georgia | GA
Guam | GU
Hawaii | HI
Idaho | ID
Illinois | IL
Indiana | IN
Iowa | IA
Kansas | KS
Kentucky | KY
Louisiana | LA
Maine | ME
Marshall Islands | MH
Maryland | MD
Massachusetts | MA
Michigan | MI
Minnesota | MN
Mississippi | MS
Missouri | MO
Montana | MT
Nebraska | NE
Nevada | NV
New Hampshire | NH
New Jersey | NJ
New Mexico | NM
New York | NY
North Carolina | NC
North Dakota | ND
Northern Mariana Islands | MP
Ohio | OH
Oklahoma | OK
Oregon | OR
Palau | PW
Pennsylvania | PA
Puerto Rico | PR
Rhode Island | RI
South Carolina | SC
South Dakota | SD
Tennessee | TN
Texas | TX
Utah | UT
Vermont | VT
Virgin Islands | VI
Virginia | VA
Washington | WA
West Virginia | WV
Wisconsin | WI
Wyoming | WY