# Appendix D ISO Country Codes for Selected Countries

Source: International Organization for Standardization. Codes for the representation of names of countries and their subdivisions. Part 1: Country codes. Geneva (Switzerland): The Organization; 1997. (ISO 3166-1: 1997).

Country | Two-letter Abbreviation | Country | Two-letter Abbreviation
Afghanistan | AF | Laos | LA
Albania | AL | Latvia | LV
Algeria | DZ | Lebanon | LB
Andorra | AD | Lesotho | LS
Angola | AO | Liberia | LR
Antigua and Barbuda | AG | Libya | LY
Argentina | AR | Liechtenstein | LI
Armenia | AM | Lithuania | LT
Australia | AU | Luxembourg | LU
Austria | AT | Macedonia | MK
Azerbaijan | AZ | Madagascar | MG
Bahamas | BS | Malawi | MW
Bahrain | BH | Malaysia | MY
Bangladesh | BD | Maldives | MV
Barbados | BB | Mali | ML
Belarus | BY | Malta | MT
Belgium | BE | Marshall Islands | MH
Belize | BZ | Mauritania | MR
Benin | BJ | Mauritius | MU
Bhutan | BT | Mexico | MX
Bolivia | BO | Micronesia | FM
Bosnia and Herzegowina | BA | Moldova | MD
Botswana | BW | Monaco | MC
Brazil | BR | Mongolia | MN
Brunei Darussalam | BN | Morocco | MA
Bulgaria | BG | Mozambique | MZ
Burkina Faso | BF | Myanmar | MM
Burundi | BI | Namibia | NA
Cambodia | KH | Nauru | NR
Cameroon | CM | Nepal | NP
Canada | CA | Netherlands | NL
Cape Verde | CV | New Zealand | NZ
Central African Republic | CF | Nicaragua | NI
Chad | TD | Niger | NE
Chile | CL | Nigeria | NG
China | CN | Norway | NO
Colombia | CO | Oman | OM
Comoros | KM | Pakistan | PK
Congo, Democratic Republic | CD | Palau | PW
Congo, People’s Republic | CG | Panama | PA
Costa Rica | CR | Papua New Guinea | PG
Cote d'Ivoire | CI | Paraguay | PY
Croatia (Local Name: Hrvatska) | HR | Peru | PE
Cuba | CU | Philippines | PH
Cyprus | CY | Poland | PL
Czech Republic | CZ | Portugal | PT
Denmark | DK | Qatar | QA
Djibouti | DJ | Puerto Rico | PR
Dominica | DM | Romania | RO
Dominican Republic | DO | Russian Federation | RU
East Timor | TL | Rwanda | RW
Ecuador | EC | Saint Kitts and Nevis | KN
El Salvador | SV | Saint Lucia | LC
Equatorial Guinea | GQ | Saint Vincent and the Grenadines | VC
Eritrea | ER | Samoa | WS
Estonia | EE | San Marino | SM
Ethiopia | ET | Sao Tome and Príncipe | ST
Fiji | FJ | Saudi Arabia | SA
Finland | FI | Senegal | SN
France | FR | Serbia and Montenegro | CS
Gabon | GA | Seychelles | SC
Gambia | GM | Sierra Leone | SL
Georgia | GE | Singapore | SG
Germany | DE | Slovakia (Slovak Republic) | SK
Ghana | GH | Slovenia | SI
Greece | GR | Solomon Islands | SB
Grenada | GD | Somalia | SO
Greenland | GL | South Africa | ZA
Guatemala | GT | Spain | ES
Guinea | GN | Sri Lanka | LK
Guinea-Bissau | GW | Sudan | SD
Guyana | GY | Suriname | SR
Haiti | HT | Swaziland | SZ
Honduras | HN | Sweden | SE
Hong Kong | HK | Switzerland | CH
Hungary | HU | Syrian Arab Republic | SY
Iceland | IS | Tajikistan | TJ
India | IN | Tanzania | TZ
Indonesia | ID | Taiwan | TW
Iran | IR | Tanzania | TZ
Iraq | IQ | Thailand | TH
Ireland | IE | Togo | TG
Israel | IL | Tonga | TO
Italy | IT | Trinidad and Tobago | TT
Jamaica | JM | Tunisia | TN
Japan | JP | Turkey | TR
Jordan | JO | Turkmenistan | TM
Kazakhstan | KZ | Tuvalu | TV
Kenya | KE | Uganda | UG
Kiribati | KI | Ukraine | UA
Korea, Democratic People's Republic | KP | United Arab Emirates | AE
Korea, Republic | KR | United Kingdom | GB
Kuwait | KW | United States | US
Kyrgyzstan | KG | Uruguay | UY