# Appendix A Abbreviations for Commonly Used English Words in Journal Titles

For a comprehensive list of title word abbreviations in many languages, or to search for an abbreviation, use the ISSN International Centre's LTWA (LTWA stands for List of Title Word Abbreviations, go to Access to the LTWA (http://www.issn.org/services/online-services/access-to-the-ltwa/)). The Centre updates this list annually.

When NLM created Citing Medicine, access to the LTWA source was only by subscription. The Centre adds new words and their abbreviations and changes abbreviations of some words over time. Because we do not regularly update the listing here (it was only updated once in 2009) and the LTWA is now free online to search or download, we have decided to remove this list from our publication.

Two general rules originally provided still apply, so we are retaining them here. The first is that you never abbreviate journal titles consisting of a single word, and the second is that you do not abbreviate journal titles in character-based languages.