# Volume 2

Section IV Technical, Legal, and Analytic Considerations for Combining Registry Data With Other Data Sources

Section V Special Applications in Patient Registries

Section VI Evaluating Registries