# Volume 1

Section I Creating Registries

Section II Legal and Ethical Considerations for Registries

Section III Operating Registries