# Evaluating Registries

25 Assessing Quality