# Special Applications in Patient Registries

19 Use of Registries in Product Safety Assessment

20 Rare Disease Registries

21 Pregnancy Registries

22 Quality Improvement Registries

23 Registries for Medical Devices

24 Public-Private Partnerships