# Technical, Legal, and Analytic Considerations for Combining Registry Data With Other Data Sources

15 Interfacing Registries With Electronic Health Records

16 Linking Registry Data With Other Data Sources To Support New Studies

17 Managing Patient Identity Across Data Sources

18 Analysis of Linked Registry Data Sets