# Operating Registries

10 Recruiting and Retaining Participants in the Registry

11 Data Collection and Quality Assurance

12 Adverse Event Detection, Processing, and Reporting

13 Analysis, Interpretation, and Reporting of Registry Data To Evaluate Outcomes

14 Modifying and Stopping Registries