# Legal and Ethical Considerations for Registries

7 Principles of Registry Ethics, Data Ownership, and Privacy

8 Informed Consent for Registries

9 Protecting Data: Confidentiality and Legal Concerns of Providers, Manufacturers, and Health Plans