# Creating Registries

1 Patient Registries

2 Planning a Registry

3 Registry Design

4 Data Elements for Registries

5 Use of Patient-Reported Outcomes in Registries

6 Data Sources for Registries