# Reviewers

The findings and conclusions in this document are those of the contributors and reviewers. The contributors and reviewers participated as individuals and not necessarily as representatives of their organizations. No statement in this document should be construed as an official position of any organization represented here.

Chapter 1 Patient Registries
- Kathleen Blake, M.D., M.P.H.
- Emma James, Ph.D.
- Bruce C. Marshall, M.D.
- Lawrence H. Muhlbaier, Ph.D.
- Anne E. Trontell, M.D., M.P.H.
- Kelly Trout, B.S.N., R.N.

Chapter 2 Planning a Registry
- Hesha J. Duggirala, Ph.D., M.P.H.
- Paul Eggers, Ph.D.
- Kathleen Hewitt, M.S.N., R.N., A.A.C.C., CPHQ
- Solomon Iyasu, M.D., M.P.H.
- Bruce C. Marshall, M.D.
- Deven McGraw, J.D., M.P.H., L.L.M.
- Lawrence H. Muhlbaier, Ph.D.
- Paul Stang, Ph.D.
- Anne E. Trontell, M.D., M.P.H.

Chapter 3 Registry Design
- Jaclyn L. F. Bosco, Ph.D., M.P.H.
- Melanie J. Harrison, M.D., M.S.C.E.
- Kathleen Hewitt, M.S.N., R.N., A.A.C.C., CPHQ
- Solomon Iyasu, M.D., M.P.H.
- Theodore Lystig, Ph.D.
- Bruce C. Marshall, M.D.
- Lawrence H. Muhlbaier, Ph.D.
- Dimitrios Pappas, M.D., M.P.H.

Chapter 4 Data Elements for Registries
- Deven McGraw, J.D., M.P.H., L.L.M.
- Lawrence H. Muhlbaier, Ph.D.

Chapter 5 Use of Patient-Reported Outcomes in Registries
- Jeanette M. Broering, R.N., Ph.D., M.P.H.
- Lori Frank, Ph.D.
- Eric Gemmen, M.A.
- Deven McGraw, J.D., M.P.H., L.L.M.
- Albert Wu, M.D., M.P.H.

Chapter 6 Data Sources for Registries
- Kathleen Blake, M.D., M.P.H.
- David C. Dale, M.D.
- Deven McGraw, J.D., M.P.H., L.L.M.
- Lawrence H. Muhlbaier, Ph.D.
- Dimitrios Pappas, M.D., M.P.H.
- Paul Stang, Ph.D.

Chapter 7 Principles of Registry Ethics, Data Ownership, and Privacy
- Kathleen Blake, M.D., M.P.H.
- Paul Eggers, Ph.D.
- Marissa Gordon-Nguyen, J.D.
- Julia G. Gorey, J.D.
- Christina M. Heide, J.D.
- Solomon Iyasu, M.D., M.P.H.
- Wendy Lipworth, M.D., Ph.D.
- Deven McGraw, J.D., M.P.H., L.L.M.
- Lawrence H. Muhlbaier, Ph.D.

Chapter 8 Informed Consent for Registries
- Paul S. Appelbaum, M.D.
- Jeanette M. Broering, R.N., Ph.D., M.P.H.
- J. Alexander Cole, D.Sc., M.P.H.
- Theresa Cullen, M.D., M.S.
- Andy DeMayo, J.D.
- Douglas S. Diekema, M.D., M.P.H.
- Paul Eggers, Ph.D.
- Barbara Evans, J.D., Ph.D.
- Richard E. Gliklich, M.D.
- Julia G. Gorey, J.D.
- Emma James, Ph.D.
- Deven McGraw, J.D., M.P.H., L.L.M.
- Yaffa Rubinstein, Ph.D.
- Michelle Tarver, M.D., Ph.D.
- Jennifer Weisman, Ph.D.
- David S. Wendler, M.A., Ph.D.

Chapter 9 Protecting Data: Confidentiality and Legal Concerns of Providers, Manufacturers, and Health Plans
- Andy DeMayo, J.D.
- Nancy A. Dreyer, M.P.H., Ph.D.
- Mark J. Fox
- Danica Marinac-Dabic, M.D., Ph.D.
- Deven McGraw, J.D., M.P.H., L.L.M.
- James G. Snell, J.D.

Chapter 10 Recruiting and Retaining Participants in the Registry
- Kathleen Blake, M.D., M.P.H.
- Eric Gemmen, M.A.
- Kelly Trout, B.S.N., R.N.

Chapter 11 Data Collection and Quality Assurance
- Theodore Lystig, Ph.D.
- Bruce C. Marshall, M.D.
- Deven McGraw, J.D., M.P.H., L.L.M.
- Paul D. Varosy, M.D.

Chapter 12 Adverse Event Detection, Processing, and Reporting
- Jaclyn L. F. Bosco, Ph.D., M.P.H.
- Julia G. Gorey, J.D.
- Vandana Menon, M.D.

Chapter 13 Analysis, Interpretation, and Reporting of Registry Data To Evaluate Outcomes
- Marcella Blackledge, B.A.
- Rosemarie Hakim, Ph.D.
- Theodore Lystig, Ph.D.
- Aaron B. Mendelsohn, Ph.D., M.P.H.

Chapter 14 Modifying and Stopping Registries
- Marcella Blackledge, B.A.
- Jack L. Cronenwett, M.D.
- David C. Dale, M.D.
- Andy DeMayo, J.D.
- Paul Eggers, Ph.D.
- Emma James, Ph.D.
- Deven McGraw, J.D., M.P.H., L.L.M.
- Yaffa Rubinstein, Ph.D.
- Kelly Trout, B.S.N., R.N.

Chapter 15 Interfacing Registries With Electronic Health Records
- Kathleen Blake, M.D., M.P.H.
- Deven McGraw, J.D., M.P.H., L.L.M.
- David C. Naftel, Ph.D.

Chapter 16 Linking Registry Data With Other Data Sources To Support New Studies
- Deven McGraw, J.D., M.P.H., L.L.M.
- Patricia Russo, Ph.D.

Chapter 17 Managing Patient Identity Across Data Sources
- Leonard D'Avolio, Ph.D.
- T. Bruce Ferguson, M.D., FAHA
- Michael Kahn, M.D., Ph.D.
- Theodore Lystig, Ph.D.
- Deven McGraw, J.D., M.P.H., L.L.M.
- J. Marc Overhage, M.D., Ph.D.
- Kelly Trout, B.S.N., R.N.

Chapter 18 Analysis of Linked Registry Data Sets
- Joseph A.C. Delaney, Ph.D.
- Mark J. Fox
- Brian C. Sauer, Ph.D., M.S.
- Art Sedrakyan, M.D., Ph.D.
- Paul Stang, Ph.D.
- Priscilla Velentgas, Ph.D.

Chapter 19 Use of Registries in Product Safety Assessment
- Kathleen Blake, M.D., M.P.H.
- Christina DeFilippo Mack, Ph.D., M.S.P.H.
- David C. Naftel, Ph.D.
- Paul D. Varosy, M.D.

Chapter 20 Rare Disease Registries
- Diane J. Aschman, M.S.
- Marcella Blackledge, B.A.
- Kathleen Blake, M.D., M.P.H.
- J. Alexander Cole, D.Sc., M.P.H.
- Barrie J. Hurwitz, M.B., MRCP
- Emma James, Ph.D.
- Robert A. Jenders, M.D., M.S., FACP, FACMI
- Catherine Koepper
- Deven McGraw, J.D., M.P.H., L.L.M.

Chapter 21 Pregnancy Registries
- Yvonne Geissbuehler, Ph.D.
- Solomon Iyasu, M.D., M.P.H.
- Emma James, Ph.D.
- Christina DeFilippo Mack, Ph.D., M.S.P.H.
- Judy A. Staffa, Ph.D., R.Ph.
- Hugh Tilson, M.D., M.P.H., Dr.P.H.

Chapter 22 Quality Improvement Registries
- Kathleen Blake, M.D., M.P.H.
- Joseph P. Drozda, Jr., M.D., FACC
- Claudia Grossmann, Ph.D.
- Clifford Ko, M.D.
- J. Michael McGinnis, M.D., M.P.P.
- David C. Naftel, Ph.D.
- Richard L. Prager, M.D.
- Karen Richards
- Hugh Tilson, M.D., M.P.H., Dr.P.H.

Chapter 23 Registries for Medical Devices
- Jay Crowley
- Hesha J. Duggirala, Ph.D., M.P.H.
- Julian M. Goldman, M.D.
- Barbara Muth
- David C. Naftel, Ph.D.
- Michael Steinbuch, Ph.D.
- Paul D. Varosy, M.D.

Chapter 24 Public-Private Partnerships
- Kathleen Blake, M.D., M.P.H.
- Mark J. Fox
- Rosemarie Hakim, Ph.D.
- Danica Marinac-Dabic, M.D., Ph.D.
- Deven McGraw, J.D., M.P.H., L.L.M.
- Marissa A. Miller, D.V.M., M.P.H.
- Elizabeth J. Swain
- Hugh Tilson, M.D., M.P.H., Dr.P.H.

Chapter 25 Assessing Quality
- Kathleen Blake, M.D., M.P.H.
- Leonard D'Avolio, Ph.D.
- Benjamin C. Eloff, Ph.D.
- Melanie J. Harrison, M.D., M.S.C.E.
- Theodore Lystig, Ph.D.
- Danica Marinac-Dabic, M.D., Ph.D.
- Barry Mirrer, M.S., CMQ/OE
- David C. Naftel, Ph.D.

We would also like to acknowledge the reviewers who contributed to previous editions of the user's guide. These reviewers are listed below in alphabetical order:

- Susan Adams, J.D.
- Steven J. Atlas, M.D., M.P.H.
- Stephen W. Bernstein, J.D.
- Jeffrey Brown, Ph.D.
- Daniel Caños
- Michael A. Carome, M.D.
- Patrice Desvigne-Nickens, M.D.
- Rachel S. Dokholyan, M.P.H.
- Pamela S. Douglas, M.D., FACC
- Nancy A. Dreyer, M.P.H., Ph.D.
- Brenda K. Edwards, Ph.D.
- Paul Eggers, Ph.D.
- Jonathan S. Einbinder, M.D., M.P.H.
- Shamiram Feinglass, M.D., M.P.H.
- Leslye K. Fitterman, Ph.D.
- Sally Flanzer, Ph.D., CIP
- Gregg C. Fonarow, M.D.
- Sarah Garner, Ph.D., B.Pharm., M.R.Pharm.S.
- Richard E. Gliklich, M.D.
- Marie R. Griffin, M.D., M.P.H.
- Thomas Gross, M.D., M.P.H.
- Joanna Haas, M.D., M.Sc.
- Rosemarie Hakim, Ph.D.
- John D. Halamka, M.D., M.S.
- Stephen C. Hammill, M.D.
- Christina M. Heide, J.D.
- Janet Hiller, M.P.H., Ph.D.
- Michael Ibara, Pharm.D.
- Peter I. Juhn, M.D., M.P.H.
- Catherine Koepper
- Rebecca D. Kush, Ph.D.
- Joseph A. Ladapo, M.D., Ph.D.
- Julia I. Lane
- Peter Littlejohns, M.D.
- Bruce C. Marshall, M.D.
- Susan McAndrew, J.D.
- Newell McElwee, Pharm.D., M.S.P.H.
- J. Michael McGinnis, M.D., M.P.P.
- Charles R. McKay, M.D., FACC
- Kristi R. Mitchell, M.P.H.
- Lawrence H. Muhlbaier, Ph.D.
- Steven E. Nissen, M.D.
- Gareth Parry, Ph.D.
- Steven Pearson, M.D.
- Eric Peterson, M.D., M.P.H.
- Steve E. Phurrough, M.D., M.P.A.
- Richard Platt, M.D., M.Sc.
- Victoria M. Prescott, J.D.
- Michael T. Rapp, M.D., J.D., FACEP
- Robert Reynolds, Sc.D.
- Gerald F. Riley, M.S.P.H.
- Sara Rosenbaum, J.D.
- Kenneth J. Rothman, Dr.P.H.
- Susan T. Sacks, Ph.D.
- Grannum Sant, M.D., FRCS, FACS
- William B. Saunders, Ph.D., M.P.H.
- Juergen Schmider, M.D., Ph.D.
- Walter L. Straus, M.D., M.P.H.
- Hugh Tilson, M.D., M.P.H., Dr.P.H.
- Anne E. Trontell, M.D., M.P.H.
- Jack V. Tu, M.D., Ph.D.
- Cunlin Wang, M.D., Ph.D.
- Suzanne L. West, M.P.H, Ph.D.
- Marcy Wilder, J.D.
- Marcus D. Wilson, Pharm.D.
- John Yee, M.D., M.P.H.