# Executive Summary

## Defining Patient Registries

This User's Guide is intended to support the design, implementation, analysis, interpretation, and quality evaluation of registries created to increase understanding of patient outcomes. For the purposes of this guide, a patient registry is an organized system that uses observational study methods to collect uniform data (clinical and other) to evaluate specified outcomes for a population defined by a particular disease, condition, or exposure, and that serves one or more predetermined scientific, clinical, or policy purposes. A registry database is a file (or files) derived from the registry. Although registries can serve many purposes, this guide focuses on registries created for one or more of the following purposes: to describe the natural history of disease, to determine clinical effectiveness or cost-effectiveness of health care products and services, to measure or monitor safety and harm, and/or to measure quality of care.

Registries are classified according to how their populations are defined. For example, product registries include patients who have been exposed to biopharmaceutical products or medical devices. Health services registries consist of patients who have had a common procedure, clinical encounter, or hospitalization. Disease or condition registries are defined by patients having the same diagnosis, such as cystic fibrosis or heart failure.

## Planning a Registry

There are several key steps in planning a patient registry, including articulating its purpose, determining whether it is an appropriate means of addressing the research question, identifying stakeholders, defining the scope and target population, assessing feasibility, and securing funding. The registry team and advisors should be selected based on their expertise and experience.

The plan for registry governance and oversight should clearly address such issues as overall direction and operations, scientific content, ethics, safety, data access, publications, and change management. It is also helpful to plan for the entire lifespan of a registry, including how and when the registry will end and any plans for transition at that time.

## Registry Design

A patient registry should be designed with respect to its major purpose, with the understanding that different levels of rigor may be required for registries designed to address focused analytical questions to support decisionmaking, in contrast to registries intended primarily for descriptive purposes. The key points to consider in designing a registry include formulating a research question; choosing a study design; translating questions of clinical interest into measurable exposures and outcomes; choosing patients for study, including deciding whether a comparison group is needed; determining where data can be found; and deciding how many patients need to be studied and for how long. Once these key design issues have been settled, the registry design should be reviewed to evaluate potential sources of bias (systematic error); these should be addressed to the extent that is practical and achievable. The information value of a registry is enhanced by its ability to provide an assessment of the potential for bias and to quantify how this bias could affect the study results.

The specific research questions of interest will guide the registry's design, including the choice of exposures and outcomes to be studied and the definition of the target population (the population to which the findings are meant to apply). The registry population should be designed to approximate the characteristics of the target population as much as possible. The number of study subjects to be recruited and the length of observation (followup) should be planned in accordance with the overall purpose of the registry. The desired study size (in terms of subjects or person-years of observation) is determined by specifying the magnitude of an expected, clinically meaningful effect or the desired precision of effect estimates. Study size determinants are also affected by practicality, cost, and whether the registry is intended to support regulatory decisionmaking. Depending on the purpose of the registry, internal, external, or historical comparison groups strengthen the understanding of whether the observed effects are indeed real and in fact different from what would have occurred under other circumstances.

Registry study designs often restrict eligibility for entry to individuals with certain characteristics (e.g., age) to ensure that the registry will have subgroups with sufficient numbers of patients for analysis. Or the registry may use some form of sampling—random selection, systematic sampling, or a haphazard, nonrandom approach—to achieve this end.

## Data Elements

The selection of data elements requires balancing such factors as their importance for the integrity of the registry and for the analysis of primary outcomes, their reliability, their contribution to the overall burden for respondents, and the incremental costs associated with their collection. Selection begins with identifying relevant domains. Specific data elements are then selected with consideration for established clinical data standards, common data definitions, and whether patient identifiers will be used. It is important to determine which elements are absolutely necessary and which are desirable but not essential. In choosing measurement scales for the assessment of patient-reported outcomes, it is preferable to use scales that have been appropriately validated, when such tools exist. Once data elements have been selected, a data map should be created, and the data collection tools should be pilot tested. Testing allows assessment of respondent burden, the accuracy and completeness of questions, and potential areas of missing data. Inter-rater agreement for data collection instruments can also be assessed, especially in registries that rely on chart abstraction. Overall, the choice of data elements should be guided by parsimony, validity, and a focus on achieving the registry's purpose.

## Use of Patient-Reported Outcomes in Registries

Patient-reported outcomes (PROs) are reports of health status taken directly from patients without interpretation by clinicians. PROs can provide useful information for registries designed for many purposes, including natural history of disease, quality improvement, effectiveness, and comparative effectiveness. Using PROs raises such questions as when and how often to collect the data, which method or combination of methods should be used (e.g., paper-based, electronic), and which instrument(s) should be used. Many validated instruments and measures are available, such as general assessment scales (e.g., health-related quality of life), disease-specific scales, symptom-specific scales, evaluations of functioning across a variety of domains (e.g., physical, social, emotional), and scales assessing satisfaction with care received. When selecting instruments or measures, it is important to define (1) the population of interest, (2) the outcomes of interest, (3) the intended users of the registry, and (4) the purpose of the registry. Defining these factors will help determine which PROs are useful and appropriate for the study. The instrument's validity, reliability, and ability to detect change should also be considered. Once PROs have been selected, the registry should focus on consistency, across patients and across sites, with respect to how the instruments are administered and how data are entered into the registry.

## Data Sources

A single registry may integrate data from various sources. The form, structure, availability, and timeliness of the required data are important considerations. Data sources can be classified as primary or secondary. Primary data are collected by the registry for its direct purposes. Secondary data have been collected by a secondary source for purposes other than the registry, and may not be uniformly structured or validated with the same rigor as the registry's primary data. Sufficient identifiers are necessary to guarantee an accurate match between data from secondary sources and registry patients. Furthermore, it is advisable to obtain a solid understanding of the original purpose of the secondary data, because the way those data were collected and verified or validated will help shape or limit their use in a registry. Common secondary sources of data linked to registries include medical records systems, institutional or organizational databases, administrative health insurance claims data, death and birth records, census databases, and related existing registry databases.

## Ethics, Data Ownership, and Privacy

Critical ethical and legal considerations should guide the development and use of patient registries. The Common Rule is the uniform set of regulations on the ethical conduct of human subjects research, issued by the Federal agencies that fund such research. Institutions that conduct research agree to comply with the Common Rule for federally funded research, and may opt to apply that rule to all human subjects activities conducted within their facilities or by their employees and agents, regardless of the source of funding. The Privacy Rule, promulgated under the Health Insurance Portability and Accountability Act of 1996 (HIPAA), establishes Federal protections for the privacy of individually identifiable health information created and maintained by health plans, health care clearinghouses, and most health care providers (collectively, “covered entities”). The purpose of a registry, the type of entity that creates or maintains the registry, the types of entities that contribute data to the registry, and the extent to which registry data are individually identifiable affect how the regulatory requirements apply. Other important concerns include transparency of activities, oversight, and data ownership. This chapter of the User's Guide focuses solely on U.S. law. Health information is also legally protected in European and some other countries by distinctly different rules.

## Informed Consent for Registries

The requirement of informed consent often raises different issues for patient registries versus clinical trials. For example, registries may be used for public health or quality improvement activities, which may not constitute “human subjects research.” Also, registries may integrate data from multiple electronic sources (e.g., claims data, electronic health records) and may be linked to biobanks. Institutional review boards may approve waivers or alterations of informed consent (e.g., electronic consent, oral consent) for some registries, depending on the purpose and risk to participants. Established registries that undergo a change in scope (e.g., changes in data sharing policies, changes to the protocol, extension of the followup period) may need to ask patients to “re-consent.” When planning informed consent procedures, registry developers should consider several factors, including documentation and format, consent revisions and re-consent, the applicability of regulatory requirements, withdrawal of participants from the study, and the physical and electronic security of patient data and biological specimens. In addition, registry developers may need to consider the individual authorization requirements of the HIPAA Privacy Rule, where applicable.

## Confidentiality and Legal Concerns for Providers, Manufacturers, and Health Plans

As patient registries are increasingly recognized as a valuable data source, questions about privacy and the confidentiality of the data arise, particularly when data are desired for litigation or other judicial or administrative proceedings. In addition to patient data, registries often include private, confidential, and/or proprietary information about providers, manufacturers, and health plans. While significant attention has been paid to protecting the privacy of identifiable patient information, there is no single comprehensive Federal law governing protection of registry data about providers, manufacturers, or health plans. Sources of protection for these data include the Patient Safety and Quality Improvement Act of 2005, the Health and Human Services Certificate of Confidentiality, the Agency for Healthcare Research and Quality Confidentiality Statute, the Privacy Act of 1974, the Federal Rules of Evidence and Civil Procedure, the Freedom of Information Act, Quality Improvement Organizations, the Federal Trade Secrets Act, and the Patient Protection and Affordable Care Act. Additional protections are available at the State level through safe harbor and peer review laws. Registry developers should consider this issue during the planning phase and clearly articulate the policies and procedures that the registry will follow in the case of a request for registry data (e.g., from litigation attorneys, regulatory authorities, the press, or members of the public).

## Patient and Provider Recruitment and Management

Recruitment and retention of patients as registry participants, and of providers as registry sites, are essential to the success of a registry. Recruitment typically occurs at several levels, including facilities (hospitals, physicians' practices, and pharmacies), providers, and patients. The motivating factors for participation at each level and the factors necessary to achieve retention differ according to the registry. Factors that motivate participation include the perceived relevance, importance, or scientific credibility of the registry, as well as a favorable balance of any incentives for participation versus the risks and burdens thereof. Because patient and provider recruitment and retention can affect how well a registry represents the target population, well-planned strategies for enrollment and retention are critical. Goals for recruitment, retention, and followup should be explicitly laid out in the registry planning phase, and deviations during the conduct of the registry should be continuously evaluated for their risk of introducing bias.

## Data Collection and Quality Assurance

The integrated system for collecting, cleaning, storing, monitoring, reviewing, and reporting on registry data determines the utility of those data for meeting the registry's goals. A broad range of data collection procedures and systems are available. Some are more suitable than others for particular purposes. Critical factors in the ultimate quality of the data include how data elements are structured and defined, how personnel are trained, and how data problems (e.g., missing, out-of range, or logically inconsistent values) are handled. Registries may also be required to conform to guidelines or to the standards of specific end users of the data (e.g., 21 Code of Federal Regulations, Part 11). Quality assurance aims to affirm that the data were, in fact, collected in accordance with established procedures and that they meet the requisite standards of quality to accomplish the registry's intended purposes and the intended use of the data.

Requirements for quality assurance should be defined during the registry's inception and creation. Because certain requirements may have significant cost implications, a risk-based approach to developing a quality assurance plan is recommended. It should be based on identifying the most important or likely sources of error or potential lapses in procedures that may affect the quality of the registry in the context of its intended purpose.

## Adverse Event Detection, Processing, and Reporting

The U.S. Food and Drug Administration defines an adverse event (AE) as any untoward medical occurrence in a patient administered a pharmaceutical product, whether or not related to or considered to have a causal relationship with the treatment. AEs are categorized according to the seriousness and, for drugs, the expectedness of the event. Although AE reporting for all marketed products is dependent on the principle of “becoming aware,” collection of AE data falls into two categories: those events that are intentionally solicited (meaning data that are part of the uniform collection of information in the registry) and those that are unsolicited (meaning that the AE is volunteered or noted in an unsolicited manner). The determination of whether the registry should use a case report form to collect AEs should be based on the scientific importance of the information for evaluating the specified outcomes of interest. Regardless of whether or not AEs constitute a primary objective of the registry, it is important for any registry that has direct patient interaction to develop a plan for detecting, processing, and reporting AEs. If the registry receives sponsorship, in whole or in part, from a regulated industry (drugs or devices), the sponsor has mandated reporting requirements including stringent timelines, and the registry should establish the process for detecting and reporting AEs and should provide training to registry personnel on how to identify AEs and to whom they should be reported. Sponsors of registries designed specifically to meet requirements for surveillance of drug or device safety are encouraged to hold discussions with health authorities about the most appropriate process for reporting serious AEs.

## Analysis, Interpretation, and Reporting of Registry Data

Analysis and interpretation of registry data begin with answering a series of core questions: Who was studied, and how were they chosen for study? How were the data collected, edited, and verified, and how were missing data handled? How were the analyses performed? Four populations are of interest in describing who was studied: the target population, the accessible population, the intended population, and the population actually studied (the “actual population”). The representativeness of the actual population to the target population is referred to as generalizability.

Analysis of registry outcomes first requires an analysis of recruitment and retention, of the completeness of data collection, and of data quality. Considerations include an evaluation of losses to followup; completeness for most, if not all, important covariates; and an understanding of how missing data were handled and reported. Analysis of a registry should provide information on the characteristics of the patient population, the exposures of interest, and the endpoints. Descriptive registry studies focus on describing frequency and patterns of various elements in a patient population, whereas analytical studies concentrate on associations between patients or treatment characteristics and health outcomes of interest. A statistical analysis plan describes the analytical plans and statistical techniques that will be used to evaluate the primary and secondary objectives specified in the study plan. Interpretation of registry data should be provided so that the conclusions can be understood in the appropriate context and any lessons from the registry can be applied to the target population and used to improve patient care and outcomes.

## Modifying and Stopping Registries

Most, if not all, registries should undergo periodic critical evaluation by key stakeholders to ensure that the objectives are being met. When registry objectives are no longer being met or when clinical or other changes affect the registry (e.g., changes in treatment practices, the introduction of a new therapy), the registry may need to be adapted, or the registry may stop collecting new data. Many registries will undergo a modification or transition at some point in their lifecycle, and these changes will vary in scope and size. A major registry transition is a change in the registry's purpose, stakeholders, and/or technology platform that has a substantive impact on the ongoing conduct of the registry. Considerations for the transition of a registry are similar to those for starting a registry, but transitions can also present some unique challenges. It is important to select a leadership team that will carefully plan and implement the transition and consider the impacts of the planned changes (e.g., legal and ethical issues, technology, and data analysis). The transition team should also be prepared to handle unplanned or exigent circumstances that may arise during the transition and modify the project plan accordingly. Open, ongoing communication between the project team, stakeholders, participants, and other resources is key to conducting a successful transition.

A registry may stop collecting new data because it has fulfilled its original purpose, is unable to fulfill its purpose, is no longer relevant, or is unable to maintain sufficient funding, staffing, or other support. If an open-ended registry is planned, reasonable goals should be set for data quality, study enrollment, and the amount of information needed to address specific endpoints of interest which will inform the decision if and when to end the registry.

## Interfacing of Registries With Electronic Health Records

Achieving interoperability between electronic health records (EHRs) and registries will be increasingly important as adoption of EHRs and the use of patient registries for many purposes both grow significantly. Such interoperability should be based on open standards that enable any willing provider to interface with any applicable registry without requiring customization or permission from the EHR vendor. Interoperability for health information systems requires accurate and consistent data exchange and use of the information that has been exchanged. Syntactic interoperability (the ability to exchange data) and semantic interoperability (the ability to understand the exchanged data) are the core constructs of interoperability and must be present in order for EHRs and registries to share data successfully. Full interoperability is unlikely to be achieved for some time. The successive development, testing, and adoption of open standard building blocks (e.g., the Healthcare Information Technology Standards Panel's HITSP TP-50) is a pragmatic approach toward incrementally advancing interoperability while providing real benefits today. Care must be taken to ensure that integration efforts comply with legal and regulatory requirements for the protection of patient privacy and the security of individually identifiable health information.

## Linking Registry Data With Other Data Sources to Support New Studies

Registry data may be linked to other data sources (e.g., administrative data sources, other registries) to examine questions that cannot be addressed using the registry data alone. Two equally weighted and important sets of questions must be addressed in the data linkage planning process: (1) What is a feasible technical approach to linking the data? (2) Is linkage legally feasible under the permissions, terms, and conditions that applied to the original compilations of each dataset? Many statistical techniques for linking records exist (e.g., deterministic matching, probabilistic matching); the choice of a technique should be guided by the types of data available. Linkage projects should include plans for managing common issues (e.g., records that exist in only one database and variations in units of measure). In addition, it is important to understand that linkage of de-identified data may result in accidental re-identification. Risks of re-identification vary depending on the variables used, and should be managed with guidance from legal and statistical experts to minimize risk and ensure compliance with the HIPAA Privacy Rule, the Common Rule, and other legal and regulatory requirements.

## Managing Patient Identity Across Data Sources

As new technologies emerge to manage electronic health care data and create new opportunities for data linkage, patient identity management (PIM) strategies and standards grow increasingly important. If shared patient identifiers exist between two data sources, data can be linked using a unique patient identifier (UPI), such as a medical record number. The concept of a universal UPI has been the subject of debate for some time. Some view the UPI as a tool to reduce administrative workload and facilitate the exchange of electronic data, while others raise serious concerns about the privacy and protection of patient-identifiable information. To date, these concerns have halted efforts to implement universal UPIs in the United States. As a result, common PIM practices in the United States include algorithms and other statistical methods to link and combine data when no shared patient identifiers are present. However, with no standardized PIM practices in place, methods can vary widely, making it difficult to ensure the accuracy and effectiveness of data linkage techniques.

## Analysis of Linked Registry Data Sets

Retrospective database studies are studies that use data collected for a primary purpose other than research (e.g., administrative databases) or data collected for specific research objectives but used to support secondary studies focused on different objectives. These studies have yielded substantial information on the incidence, prevalence, and outcomes of many diseases and can be used to generate a rapid response to emerging research questions. However, these studies require special considerations related to conduct and interpretation because of the possibility of producing biased or invalid results. Challenges faced by retrospective database studies include inaccurate measurement of exposures, outcomes, and confounders and overweighting of results because of the large study population. To avoid these pitfalls, it is important to clearly define the study objective, patient population, and potential confounders and modifiers. Researchers must also understand the conditions under which the data were collected originally.

## Use of Registries for Product Safety Assessment

Whether as part of a postmarketing requirement or out of a desire to supplement spontaneous reporting, prospective product and disease registries are also increasingly being considered as resources for examining unresolved safety issues and/or as tools for proactive risk assessment in the postapproval setting. Registries can be valuable tools for evaluating product safety, although they are only one of many approaches to safety assessments. When designing a registry for the purposes of safety, the size of the registry, the enrolled population, and the duration of followup are all critical characteristics to ensure validity of the inferences made based on the data collected. Consideration in the design phase must also be given to other recognized aspects of product use in the real world (e.g., the switching of therapies during followup, the use of multiple products in combination or in sequence, dose effects, delayed effects, and patient compliance).

Registries designed for safety assessment should also formulate a plan that ensures that appropriate information will reach the right stakeholders (through reporting either to the manufacturer or directly to the regulator) in a timely manner. Stakeholders include patients, clinicians, providers, product manufacturers and authorization holders, and payers such as private, State, and national insurers. Registries not designed specifically for safety assessment should, at a minimum, ensure that standard reporting mechanisms for AE information are described in the registry's standard operating procedures and are made clear to investigators.

## Rare Disease Registries

A rare disease registry can be a valuable tool for increasing understanding of the disease and supporting the development of treatment protocols and therapies. Typical goals of a rare disease registry include generating knowledge around the natural history, evolution, risk, and outcomes of a specific disease; supporting research on genetic, molecular, and physiological basis of a disease; establishing a patient base for evaluating drug, medical devices, and orphan products; and facilitating connections among affected patients, families, and clinicians.

Stakeholders often play an important role in rare disease registries. Stakeholders may include patient advocacy groups, regulatory, funding, and public health agencies, clinicians, scientists, industry, payers, and individuals and families. Because of their limited patient population, rare disease registries face unique planning and design challenges. For example, little information may be available on the disease to guide development of a research plan, and diagnostic criteria may be complex or evolving. Disease-specific patient-reported outcome measures may not be available. Long-term (even lifelong) followup may be needed. Due to these challenges, rare disease registries may need to adapt and change over time as knowledge increases or treatments become available. Retention of patients and providers can also be difficult over the duration of the registry, and registry developers should monitor followup rates over time to identify potential issues. Clear policies should be developed for governance, data access, and publications, particularly if multiple stakeholders are involved.

## Pregnancy Registries

A pregnancy exposure registry is an observational prospective cohort of women receiving a biopharmaceutical product(s) of interest as part of their routine clinical care who are enrolled voluntarily during gestation, before outcomes can be known. Participants are followed until the end of pregnancy or longer to systematically collect information on specific pregnancy outcomes and evaluate their frequency relative to a scientifically valid reference population(s). While pregnancy registries are an efficient method for evaluating the effects of medications used during pregnancy, they present unique challenges related to patient recruitment and retention, the choice of reference or comparator groups, ways of mitigating bias, and generalizability of registry results. Analysis and interpretation of data from pregnancy registries also requires careful consideration. Because specific birth defects are rare events, pregnancy registries usually do not have sufficient sample size/power to evaluate increased risks for specific defects unless the relative risks are quite large. Most registries compare the overall proportion of all major defects combined in the exposed group to the overall proportion in the reference group.

## Quality Improvement Registries

Quality improvement (QI) registries use systematic data collection and other QI tools to improve the quality of care on the local, regional, or national level. In a QI registry, patients are either exposed to a particular health service (e.g., a procedure registry), or they have a disease/condition that is tracked over time through multiple health care providers and services. Most of the steps for planning a QI registry are similar to the steps used for other types of registries, with two major differences. First, the identification of active, engaged participants, often called “champions,” is critical for the early success of the registry. Second, the registry must collect actionable information that can be used to modify behaviors, processes, or systems of care. Actionable information is typically presented to providers in the form of process of care or quality measures. The selection of these measures requires balancing the goals of the registry with the desire to meet other needs for providers. In the design phase, QI registries can use the process of care or quality measures to drive the selection of data elements. Because many data elements collected in QI registries are often collected for other purposes (e.g., claims, medical records), integration with other data sources may be important for encouraging participation. Motivations for participation often differ from other types of registries, and incentives for participation focus on QI (e.g., recognition programs, QI tools, and benchmarking reports). Reporting information is also an important component of QI registries. Registries may report blinded or unblinded data at the individual patient, provider, or institution level. Lastly, QI registries must be able to adapt to new evidence and improvements in care over time, and they may face questions from institutional review boards less familiar with these types of registries.

## Registries for Medical Devices

Medical device registries are an increasingly important tool for capturing patients' experience with medical devices throughout the device lifecycle. Registries help bridge the gap between device performance in clinical trial settings and in routine practice. However, the unique features of medical devices require special consideration when developing a registry. Regulations and approval guidelines for medical devices differ greatly from those for drugs. Compared with drugs, device technologies tend to see more rapid change over shorter time periods, and device registries must adapt to these changes. The current lack of unique device identifiers is also challenging— although efforts are underway to create them. In many cases, multiple devices are used, and devices may be used in combination with a drug component, further complicating efforts to examine safety and effectiveness. In addition, providers may have different levels of experience with the device, which may affect patient outcomes (especially with implantable devices). Medical device registries should attempt to classify all parts of a device with as much identifying information as possible. Many registries collect information on provider training and experience as well. An emerging trend is the ability for medical devices to transmit data directly to an electronic health record or registry. This new technology may reduce the burden of data entry for registries and improve the timeliness of registry data.

## Public-Private Partnerships

A public-private partnership (PPP) refers to any partnership in which one entity is a public agency (e.g., a government entity) and the other entity is a private organization. PPPs are increasingly used as a means to develop patient registries, in part because of a growing interest from governments and payers in using registry data to make decisions about approval, coverage, and public health needs. Many models for PPPs exist. For example, a PPP may involve a partnership with Federal agencies and academia, health agencies from several countries and industry, or professional associations and public payers. During the planning phase of a PPP, it is important to define clear, transparent plans for governance, with documented roles for each stakeholder. Formal policies for analyses, publications, and data sharing are also critical, as are plans for managing conflicts of interest. During the operational phase, PPPs should focus on consistent communication with stakeholders to maintain their interest. PPP registries are more likely to succeed if they have clear, agreed-upon goals; explicit roles and responsibilities for each stakeholder; strong leaders who are respected in the field; consistent data collection and analysis plans; and the flexibility to adapt to changing conditions.

## Evaluating Registries

Although registries can provide useful information, there are levels of rigor that enhance validity and make the information from some registries more useful for guiding decisions. The term “quality” can be applied to registries to describe the confidence that the design, conduct, and analysis of the registry can be shown to protect against bias and errors in inference—that is, erroneous conclusions drawn from the registry. Although there are limitations to any assessment of quality, a quality component analysis is used both to evaluate high-level factors that may affect results and to differentiate between research quality (which pertains to the scientific process) and evidence quality (which pertains to the data/ findings emanating from the research process). Quality components are classified as either “basic elements of good practice,” which can be viewed as a checklist that should be considered for all patient registries, or as “potential enhancements to good practice,” which may strengthen the value of the information in particular circumstances. The results of such an evaluation should be considered in the context of the disease area(s), the type of registry, and the purpose of the registry, and should also take into account feasibility and affordability.