# Preface

This project was performed under a contract from the Agency for Healthcare Research and Quality (AHRQ) in collaboration with the Centers for Medicare & Medicaid Services (CMS) through the Developing Evidence to Inform Decisions about Effectiveness (DEcIDE) Network of AHRQ's Effective Health Care (EHC) Program. The purpose of the project was to update and expand Registries for Evaluating Patient Outcomes: A User's Guide. The User's Guide was first published in 2007 as a reference for establishing, maintaining, and evaluating the success of registries created to collect data about patient outcomes. The second edition, which provided updates to the existing topics and addressed four new topics, was published in 2010. The purpose of this revised and expanded third edition is to incorporate information on new methodological and technological advances into the existing chapters and to add 11 new chapters to address emerging topics in registry science.

Both the 2007 and 2010 versions and this third edition were created with support from a large group of stakeholders. Following award of the initial project on September 29, 2005, we created a draft outline for the document, which was posted for public comment on AHRQ's Effective Health Care Web site (http://www.effectivehealthcare.ahrq.gov) from January through March 2006. During that same period, we worked with AHRQ to create a process for selecting contributors and reviewers. We broadly solicited recommendations from a range of stakeholders, including government agencies, industry groups, medical professional societies, and other experts in the field; conducted a review of the pertinent literature; and contacted the initial list of contributors to confirm their interest and area of expertise and to seek further recommendations. Through that process and in collaboration with AHRQ and CMS, we arrived at a set of contributors and reviewers based on subject/content expertise, practical experience, and interest and availability, with balanced representation from key stakeholder groups for nearly all chapters. In addition, a request for submission of real-world case examples that could be used in the user's guide to illustrate issues and challenges in implementing registries was posted on the Effective Health Care Web site. The primary selection criteria for these examples concerned their utility in illustrating a practical challenge and its resolution.

An initial meeting of contributors was convened in February 2006. A second meeting including contributors and chapter reviewers was held in June 2006, following creation of an initial draft document and focused review by the reviewers. The collaborative efforts of contributors, reviewers, and editors resulted in a draft document that was posted for public comment on the Effective Health Care Web site in October and November 2006. In all, 39 contributors and 35 individual reviewers participated in the creation of the first document, which was released in April 2007 and has been published online and in print.

In August 2008, the user's guide update project was awarded. The project involved revising the existing chapters and case examples, creating new content to address four topics, and soliciting new case examples. From September to November 2008, we worked with AHRQ to select contributors and content reviewers for the new user's guide. We followed a process similar to that used in the creation of the original user's guide to arrive at a set of contributors and reviewers with subject matter expertise and a broad range of perspectives. The contributors drafted white papers on four topics: use of registries in product safety assessment, when to stop a registry, interfacing registries and electronic health records, and linking registry data. The white papers were reviewed and discussed at a meeting in April 2009. The papers were then posted for public comment in August and September 2009. After the papers were revised in response to public comments, the final papers were included in the expanded user's guide.

During the same timeframe, we contacted the authors and reviewers of the 2007 version of the user's guide. We asked authors and reviewers to update the existing chapters to address any new methodological, technological, or legal topics. The revised chapters were circulated for review and discussed at a meeting in July 2009. We also posted a new call for case examples on the Effective Health Care Web site in June 2009. The primary selection criteria for the new examples concerned their utility in illustrating issues and challenges related to the new topics addressed in the white papers. In addition, we contacted authors of the original case examples to obtain updated information on the registries. In all, 55 contributors and 49 individual reviewers participated in the creation of the second edition, which was published in September 2010.

The project to create the third edition of the user's guide was awarded in September 2010. The project involved revising the existing chapters and case examples, creating new content to address 11 topics, and soliciting new case examples. From October to December 2010, we followed a process similar to that used in the creation of the second edition to select contributors and reviewers with subject matter expertise and a broad range of perspectives. Beginning in January 2011, contributors drafted white papers on 11 new topics: registry transitions, analyzing linked datasets, patient identity management, informed consent for registries, protection of registry data, public-private partnerships, using patient-reported outcome measures in registries, rare disease registries, pregnancy registries, quality improvement registries, and medical device registries. The white papers were reviewed and discussed at a series of meetings held between July and October 2011. The papers were then posted for public comment in the spring and summer of 2012. After the papers were revised in response to public comments, the final papers were included in the expanded user's guide.

During the same timeframe, we contacted the authors and reviewers of the 2010 version of the user's guide. We asked them to update the existing chapters to address any new methodological, technological, or legal topics. The revised chapters were circulated for review and discussed at a meeting in July 2012. We also posted a new call for case examples on the Effective Health Care Web site in the spring of 2012. The primary selection criteria for the new examples concerned their utility in illustrating issues and challenges related to the new topics addressed in the white papers. In addition, we contacted authors of the original case examples to obtain updated information.

For all three editions, the contributors and reviewers participated as individuals and not necessarily as representatives of their organizations. We are grateful to all those who contributed to these documents, and who reviewed them and shared their comments.

To begin the discussion of registries, we would like to clarify some distinctions between registries and clinical trials. Although this subject is discussed further in Chapter 1, we offer here the following distinctions from a high-level perspective. A clinical trial is an experiment in which an active intervention intended to change a human subject's outcome is implemented, generally through a randomization procedure that takes decisionmaking away from the practitioner. The research protocol describes inclusion and exclusion criteria that are used to select the patients who will participate as human subjects, focusing the experiment on a homogeneous group. Human subjects and clinical researchers agree to adhere to a strict schedule of visits and to conduct protocol-specific tests and measurements.

In contrast, registries use an observational study design that does not specify treatments or require any therapies intended to change patient outcomes (except insofar as specific treatments or therapies may be inclusion criteria). IInclusion and exclusion criteria are kept to a minimum in an effort to study a broad range of patients in order to make the results more generalizable. Patients are typically observed as they present for care, and the data collected generally reflect whatever tests and measurements a provider customarily uses.

Patient registries represent a useful tool for a number of purposes. Their ideal use and their role in evidence development, design, operations, and evaluation resemble but differ from clinical trials in a number of substantive ways, and therefore they should not be evaluated with the same constructs. This user's guide presents what the contributors and reviewers consider good registry practices. Many registries today may not meet even the basic practices described. On the whole, registry science is in an active state of development. This third edition of the user's guide is an important step in developing the field.

This book is divided into two volumes and six sections. Volume 1 includes the first three sections: Creating Registries; Legal and Ethical Considerations for Registries; and Operating Registries. Volume 2 includes: Technical, Legal, and Analytic Considerations for Combining Registry Data with Other Data Sources; Special Applications in Registries; and Evaluating Registries.

The first three sections provide basic information on key areas of registry development and operations, highlighting the spectrum of practices in each of these areas and their potential strengths and weaknesses. Section I, “Creating Registries,” contains six chapters. “Patient Registries” defines and characterizes types of registries, their purposes, and uses, and describes their place within the scope of this document. “Planning a Registry” focuses on the recommended steps in planning a registry, from determining if a registry is the right option to describing goals and objectives. “Registry Design” examines the specifics of designing a registry once the goals and objectives are known. “Data Elements for Registries” provides a scientific and practical approach to selecting data elements. “Use of Patient-Reported Outcomes in Registries” discusses the role that patient-reported outcome measures play in registries and addresses factors in selecting and using these types of measures. “Data Sources for Registries” describes how existing data sources (administrative, pharmacy, other registries, etc.) may be used to enhance the value of patient registries.

Section II, “Legal and Ethical Considerations for Registries,” contains three chapters. “Principles of Registry Ethics, Data Ownership, and Privacy” reviews several key legal and ethical issues that should be considered in creating or operating a registry. “Informed Consent for Registries” discusses how the requirements of informed consent for patient registries differ from those for clinical trials and offers suggestions for creating informed consent documents that address the unique aspects of registries. “Protecting Data: Confidentiality and Legal Concerns of Providers, Manufacturers, and Health Plans” reviews the legal protections available for data about providers, manufacturers, and health plans contained in registries.

Section III, “Operating Registries,” provides a practical guide to the day-to-day operational issues and decisions for producing and interpreting high-quality registries. “Recruiting and Retaining Participants in the Registry” describes strategies for recruiting and retaining providers and patients. “Data Collection and Quality Assurance” reviews key areas of data collection, cleaning, storing, and quality assurance for registries. “Adverse Event Detection, Processing, and Reporting” examines relevant practical and regulatory issues. “Analysis, Interpretation, and Reporting of Registry Data To Evaluate Outcomes” addresses key considerations in analyzing and interpreting registry data. “Modifying and Stopping Registries” discusses the process of modifying an existing registry as well as considerations for determining when to end a registry.

Section IV, “Technical, Legal, and Analytic Considerations for Combining Registry Data with Other Data Sources,” reviews several issues related to the emerging trend of linking or integrating registry data with other data sources, such as electronic health records, administrative databases, or other registries.

“Interfacing Registries With Electronic Health Records” describes the current state of electronic health record (EHR) integration technology and maps out potential options for developing interfaces between registries and EHRs. “Linking Registry Data With Other Data Sources To Support New Studies” discusses the technical and legal issues surrounding the linkage of registry data with other data sources. “Managing Patient Identity Across Data Sources” reviews the options and strategies for linking patient information stored in multiple databases without the use of full personal identifiers. “Analysis of Linked Registry Data Sets” addresses issues that must be considered when analyzing combined or linked registry data, as well as issues related to using registry data to support secondary research studies.

Section V, “Special Applications in Patient Registries,” highlights several specific types of patient registries that face unique challenges. “Use of Registries in Product Safety Assessment” describes the utility and challenges of designing a registry to assess safety. “Rare Disease Registries” discusses the increasing interest in using registries to study rare diseases and the related challenges in design, recruitment, retention, and analysis. “Pregnancy Registries” reviews the value of registries for understanding the effects of medication used during pregnancy and the challenges related to design, recruitment, analysis, and dissemination of results. “Quality Improvement Registries” examines the ability of registries to support efforts to improve quality of care through the use of specialized tools and reports. “Registries for Medical Devices” addresses the unique aspects of medical devices that must be considered in the development and analysis of a device-based registry. “Public-Private Partnerships” provides a review of public-private partnership models for supporting registries as well as a discussion of major considerations for planning and operating a registry using this type of model.

Interspersed throughout the first five sections of the user's guide are case examples. As discussed above, the choice of examples was limited to those submitted for consideration during the 2006, 2009, and 2012 public submission periods. Their purpose is solely to illustrate specific points in the text using real-world examples, regardless of whether the source of the example is within the scope of the user's guide as described in Chapter 1. Inclusion of a case example is not intended as an endorsement of the quality of the particular registry, nor do the case examples necessarily present registries that meet all the criteria described in Chapter 25 as essential elements of good practice. Rather, case examples are introduced to provide the reader with a richer description of the issue or question being addressed in the text. In some cases, we have no independent information on the registry other than what has been provided by the contributor.

Section VI is “Evaluating Registries.” This final chapter on “Assessing Quality” summarizes key points from the earlier chapters in a manner that can be used to review the structure, data, or interpretations of patient registries. It describes good registry practice in terms of “essential elements” and “further indicators of quality.” This information might be used by a person developing a registry, or by a reviewer or user of registry data or interpretations derived from registries.

- Richard E. Gliklich
  Nancy A. Dreyer
  Senior Editors
- Michelle B. Leavy
  Editor