# Acknowledgements

The editors would like to acknowledge the efforts of the following individuals who contributed to the third edition of this document: Daniel Campion and Laura Khurana of Quintiles Outcome and Elise Berliner, Scott R. Smith, Sandy Cummings, Chris Heidenrich, and Frances Eisel of the Agency for Healthcare Research and Quality. We would especially like to thank Marion Torchia, who served as the managing editor for AHRQ for this User's Guide.