# Assessing Quality

## 1 Introduction

As described throughout this guide, registries are created for many purposes, including scientific, clinical, and policy. Registries may also serve more than one purpose and potentially may add or change purposes over time. This leads to variations in design, operations, or quality assurance that are sometimes viewed as methodological inadequacies. It is not generally appreciated that the attributes important for some purposes may be less important for others. As a result, it is important to distinguish these purposes with respect to recommending particular practices.

For example, in describing a very rare disease or small subgroup of patients for whom there is little other information, some relevant data from a registry are better than no data. Further, even registries that fall short of including many of the essential elements of good registry practice described in this chapter may still provide valuable insights for some purposes. As a general rule, quality should be evaluated by elements that directly impact the ability of the registry to achieve its main objectives. In other words, a registry must be fit for its purpose.

Nonetheless, while all registries can provide useful information, there are levels of rigor that enhance validity and make the information from some registries more useful for guiding decisions than others. For example, there are certain practices that enhance the validity and reliability of registries intended to evaluate safety and comparative effectiveness in terms of design and confirmation of key outcomes.

Prior to the publication of the first edition of this User's Guide,1 no criteria had been developed to guide evaluation of registries. Research into the quality aspects of registries, whatever their purpose, remains relatively sparse, especially when compared with the rich information available to guide quality in clinical trials. The aim of this chapter is to provide a simple and user-friendly listing of attributes and practices that allow registries to be described and evaluated for their essential elements and enhancements in the context of the purpose for which they are conducted. Information is presented to help distinguish between—

- Essential registry practices that are desirable for every study.
- Practices that could enhance scientific rigor and that are particularly important for certain purposes, but may not be achievable because of practical constraints.

The items listed as “essential” elements of good practice are applicable to all patient registries. While it may not be practical or feasible to achieve all of the essential elements of good practice, it is useful to consider these characteristics in planning and evaluating registries. It is also important to remind readers that some of the fundamental differences between clinical trials and registries affect how quality is evaluated. For example, a clinical trial will have a rigorously maintained schedule of visits and assessment. A clinical trial patient who does not adhere to the schedule may be viewed as noncompliant with the protocol and potentially could be discontinued from the trial. In a registry, treatments and assessments may be recommended but the registry participant who does not adhere to the schedule typically is allowed to remain in the registry, and this is considered good practice. Moreover, some argue that the kind of data produced by registries may be more valid for inferences needed in clinical decisionmaking because few exclusion criteria are used and inferences are drawn from measurements customarily used by clinicians.2

The information described in this User's Guide, and particularly in this chapter, is also designed to be used in reporting registry study results, much as CONSORT (Consolidated Standards of Reporting Trials) guidelines have been used to improve reporting of clinical trials,3 and STROBE (Strengthening the Reporting of Observational Studies in Epidemiology) guidelines are being used for observational studies.4, 5

## 2 Defining Quality

This chapter has adapted a definition of quality that was developed for randomized controlled trials;6 the term is used to refer to the confidence that the design, conduct, and analysis of the trial or registry can be shown to protect against bias (systematic error) and errors in inference—that is, erroneous conclusions drawn from a study.7 As used here, quality refers both to the data and to the conclusions drawn from analyses of these data. For more information about the types of biases that can affect observational studies, as well as strategies for addressing and even avoiding these biases to the extent feasible, see Chapters 3 and 13. For more information about bias, validity, and inference, readers are encouraged to consult epidemiologic textbooks.8-11

## 3 Measuring Quality

There are two major difficulties with assessing quality in registries:

- It can often be difficult to differentiate between the quality of the design, the study conduct, and the resultant information available.
- There is a lack of empirical evidence for evaluating the parameters purported to indicate quality and their impact on the utility of the evidence produced from registries.

Evaluations of the quality of any registry must be done with respect to the essential elements of the registry and those aspects that are important in the context of the registry's main purpose and the purpose for which the data are being used. Both the internal and external validity of the data must be taken into account along with considerations of cost and feasibility.

The most commonly used method to assess quality of studies is a quality scale; there are numerous quality scales of varying length and complexity in existence, with strong opinions both for and against their use.,6, 8,12 Different scales emphasize distinctive dimensions of quality and therefore can produce disparate results when applied to a given study. In most situations, a summary score is derived by adding individual item scores, with or without weighting. This method however, ignores whether the various items may lead to a bias toward the null (suggesting the erroneous interpretation that there is no effect) or tend to exaggerate the appearance of an effect when none really exists, and the final score produced does not reflect individual components.13 Furthermore, validation of the scales is difficult; studies have found wide variation in the scores for a particular study both by different reviewers and the same reviewers at different times.14

The approach suggested here is to undertake a quality component analysis, which involves an investigation of the components that may affect the results obtained. In the quality component analysis, a differentiation is made between two domains: research quality, which pertains to the scientific process (in this instance, the design and operational aspects of the registry), and evidence quality, which relates to the data/findings emanating from the research process.15-17 According to Lohr,18 “[t]he level of confidence one might have in evidence turns on the underlying robustness of the research and the analysis done to synthesize that research.” The individual items highlighted as essential elements of good practice and evidence quality can be used to guide the evaluation of registries, though there are no criteria as yet as to what proportion of elements must be satisfied in order to be considered “good enough” for various purposes.

To select the quality components for analysis, several key elements identified in previous research studies, among many consulted were Guidelines for Good Pharmacoepidemiology Practice,19 the ICH (International Conference on Harmonisation of Technical Requirements for Registration of Pharmaceuticals for Human Use) Guideline on Good Clinical Practice,20 the Council for International Organizations of Medical Sciences (CIOMS) International Guidelines for Ethical Review of Epidemiological Studies,21 standards developed for the conduct of registry studies for patient-centered-outcomes research,22 various reports on rating scientific evidence from observational studies12, 23 and surveillance systems,24 Goldberg's review of registry evaluation methods,25 the MOOSE (Meta-analysis of Observational Studies in Epidemiology) proposal,26 the EULAR (European League Against Rheumatism) task force on biologic registers,27 and Guidance for Reporting Observational Studies maintained by the Equator Network.28 Special purpose quality guidance documents, including the GRACE principles for observational studies of comparative effectiveness (see http://www.graceprinciples.org),29 were also reviewed.

The results of the quality component analysis must be considered in terms of the registry purpose and in the context of the disease area (See Table 25–1.) For example, a disease-specific registry that has been designed to look at natural history should not be deemed low quality simply because it is not large enough to detect rare treatment effects.

Table 25–1 Overview of registry purposes

- Determine clinical effectiveness, cost effectiveness, or comparative effectiveness of a test or treatment, including evaluating the acceptability of drugs, devices, or procedures for reimbursement.; - Measure or monitor safety and harm of specific products and treatments, including conducting comparative evaluation of safety and effectiveness.; - Measure or improve quality of care, including conducting programs to measure and/or improve the practice of medicine and/or public health.; - Assess natural history, including estimating the magnitude of a problem; determining the underlying incidence or prevalence rate; examining trends of disease over time; conducting surveillance; assessing service delivery and identifying groups at high risk; documenting the types of patients served by a health provider; and describing and estimating survival.

## 4 Quality Domains

The quality domains shown here reflect the domains described earlier in this User's Guide and have also been adapted from work undertaken for clinical trials. For research, the quality domains are research design and processes and procedures, which address planning, design, data elements and data sources, and ethics, privacy, and governance. Table 25–2 shows the essential elements of good registry practice for research, and Table 25–3 shows optional indicators of quality that may enhance registry validity and reliability, subject, of course, to feasibility and applicability.

Table 25–2 Research quality—essential elements of good practice for establishing and operating registries

Research Design
- Develop objectives and/or research questions (main and supporting, as needed).; - Identify the target population, eligibility, and inclusion and exclusion criteria. For registries where practice characteristics may influence outcome, seek to include diverse clinical practices. Where possible, a broad range of patients (few exclusion criteria) is desirable to facilitate subgroup analysis.; - Identify important personal identifiers, exposures, risk factors, and mitigating (or protective) factors, and seek those that are reasonably feasible to collect. Use the literature to inform the choice of data elements.; - Choose outcomes that are clinically meaningful and relevant to patients and to the medical community for decisionmaking. Define patient outcomes clearly, especially for complex conditions or outcomes that may not have uniformly established criteria (e.g., define “injection site reaction” in operational terms). Consider whether these outcomes will be collected from medical care providers, patients, or other observers.; - Use validated scales and tests when such tools exist for the purpose needed.; - Understand the followup time required to detect events of interest and whether or not the objective is feasible to achieve. Ensure that the followup time planned is adequate to address the main objective.; - Plan the main analyses, including specification of exposure and effect measures.; - Consider the size required to detect an effect should one exist, or to achieve a desired level of precision. Consider whether or not the sample size requirement can be achieved within the available time and budget constraints.; - Consider the most efficient and reliable means to consistently collect data of sufficient quality to meet the registry's purpose and whether existing data can be used to supplement or minimize active data collection.; - Plan to report safety events according to regulatory requirements.; - Plan the data analysis to address the key objectives or research questions, including what comparative information, if any, will be used to support study hypotheses or objectives.
Processes and Procedures
- At the outset, reach agreement on key aspects of the registry and document them, including the goals, design, target population, methods for data collection, data elements and sources, high-level data management and data quality review, and how human subjects will be protected. It may be helpful for stakeholders to have input to ensure clinical relevance and feasibility.; - Establish a process for documenting any modifications to the plan, since the main objective may change over time as knowledge accumulates, and the plan for data collection and followup may need to be adapted.; - Carefully consider the issues of protection of human subjects—including privacy, informed consent, data security, and study ethics—and address them in accordance with local, national, and international regulations. Obtain review and approval by any required oversight committees (e.g., ethics committee, privacy committee, or institutional review board as applicable). If linkage of registry data to other sources is planned consider the additional issues of protection of human subjects.; - Define the role of any external sponsor, including data access and use.; - Provide clear, operational definitions of outcomes and other data elements. Establish a data and coding dictionary to provide explicit definitions and to describe coding used. Whenever possible, use standardized data dictionaries, such as the International Classification of Diseases, and use coding that is consistent with nationally or internationally approved coding systems to promote comparability of information among studies.; - If linkage of registry data to other sources is planned consider any additional requirements that may influence successful linkage, such as selection of data elements and definitions used.; - Plan subject and physician recruitment targets and methods to achieve those targets, and plan the means for monitoring enrollment and retention.; - Plan to expend reasonable efforts to ensure that appropriate patients are enrolled systematically and followed in as unbiased a manner as possible.; - Identify appropriate personnel and facilities, including those for secure data storage. Identify the individual(s) responsible for the integrity of the data, computerized and hard copy, and make sure these individuals have the training and experience to perform the assigned tasks.; - Develop standard instructions for use in training data collectors. For safety studies, create a process for identifying and reporting serious events that is consistent with regulatory requirements. Plan training for study personnel about how to identify serious events, including:; – Asking about complaints or adverse events in a manner that is clear and specific (e.g., solicited vs. unsolicited).; – Knowing if and how information should be reported to manufacturers and health authorities.; - Create a quality assurance plan that addresses data editing and verification. Plan an approach for handling missing data (e.g., go back and collect those data or make a plan as to how “missing” data will be coded in the data files.); - Anticipate how study results will be communicated on completion.

Table 25–3 Research quality—further indicators of quality for establishing and operating registries (optional)

Research Design
- Formalize the study plan as a research protocol.; - For comparative effectiveness and safety—; – Use concurrent comparators, since they may offer an advantage over historical or external comparison groups, especially in situations where treatments are evolving rapidly. The comparator cohort should be as similar as possible to the exposed cohort, aside from the exposure under study, and should reflect current clinical practice.; – Use formal statistical calculations to specify the number of patients or patient-years of observation needed to measure an effect with a certain level of precision or to meet a specified statistical power to detect an effect should one exist, although the desired size may not be achievable within the practical study constraints. Temper considerations about precision and power with budgetary and feasibility constraints, while also giving heed to the importance of conducting research in areas where little information exists.; - Develop formal analysis plans.; - Collect information to permit linkage (and therefore validation) with external databases such as the National Death Index, electronic health records, or claims data sets, as appropriate.; - Post the registry on a public registry of registries (e.g., at the Registry of Patient Registries) or trials listing (e.g., at ClinicalTrials.gov).
Processes and Procedures
- Undertake a feasibility study or pilot test (e.g., when studying hard-to-reach populations, when sensitive data are sought, and when critical registry methods are new or have not otherwise been tested).; - When capturing composite scores, collect and record core components, if possible.; - Collect information on start and stop dates of treatments of interest and dose (if relevant) or other means to discriminate between high and low exposure.; - Use similar methods of followup for exposure and comparison cohorts, and for all subjects in each cohort, to the extent feasible.; - To enhance transparency, consider using an advisory board particularly a board that includes members who are external to the clinician, center, or company that sponsors the research. An advisory board or steering committee can promote clinical and public health relevance and may assist with governance and communication. If using an advisory board consider rotating membership and/or term limits.; - Specify publication policies in advance of collecting data and reevaluate at regular intervals (e.g., annually).; - Develop a plan for stopping or transitioning the registry, including any archiving or transferring of data and notifying participants, as appropriate.; - Consider when and how to allow third parties access to data, if feasible, and the process for any such data access; - For safety and comparative effectiveness—; – Data collection methods should not limit site participation to the extent that the representativeness of sites is compromised. Although a single method of data collection is most efficient, multiple methods of data collection may be desirable for some purposes.; – Loss to followup should be monitored and characterized to ensure that followup is sufficiently complete for the main objective and to see if there is differential loss to followup by characteristics that may affect the likelihood of achieving the main objectives. Reasonable resources should be devoted to minimizing loss to followup.; – Quality assurance (QA) may include review or monitoring of a sample of data and/or data review by an adjudication committee for complex conditions or endpoints for which established procedures and/or coding are not used. For most purposes, a risk-based strategy should be used for QA, focused on detecting and quantifying the most likely causes of error and the types of error most likely to affect the registry purpose, with QA activities adapted based on observed performance (e.g., increase QA for sites that appear to be having difficulty in study conduct or data entry).; - For safety, comparative effectiveness, and quality improvement—; – Maintain appropriate documentation, such as an audit trail, to ensure proper handling of information and to support transparency.; – Establish processes and standards for creating analytic data files and maintaining such files to support publications and presentations, since registry analyses may be performed on live data (data that may change as the registry continues to collect and verify information through various quality control procedures) or on data that have been locked and have undergone formal review and editing.; – Use open standard approaches to interoperability when health information systems are used for active data collection to permit more efficient collection of data from multiple systems.

For evidence, the quality domains are external validity, internal validity, and analysis and reporting. Table 25–4 shows the essential elements of good registry practice for evidence, and Table 25–5 shows optional further indicators of quality, including those important for selected purposes. It is important to weigh efforts to promote the accuracy and completeness of evidence in balance with the public health urgency of a problem, the types of interventions that are available, and the risks to public health from coming to a wrong conclusion. These lists of components are most likely incomplete, but the level of detail provided should be useful for high-level quality distinctions.

Table 25–4 Essential indicators of good evidence quality for registries

External Validity
- External validity was demonstrated by showing that registry participants were similar to the target population and to the extent feasible, efforts were devoted to minimizing selection bias (e.g., rules for sequential enrollment were developed and codified in a manner that worked for all sites).; - Completeness of information on eligible patients was evaluated and described.
Internal Validity
- For safety studies, a clear and specific approach was used (e.g., solicited vs. unsolicited) to ask about complaints or adverse events.; - Necessary information was collected for relevant key exposures, risk factors, and mitigating or protective factors.; - Exposure data used to support the main research questions were as specific as possible. For example, a specific product, including manufacturer, was identified to the extent feasible.; - Data checks were employed using range and consistency checks.; - For comparative effectiveness and safety—; – Followup period was reasonably sufficient to capture the main outcomes of interest.; – Comparators reflect current practice.; – A sample of data was validated with patient records, (e.g., 10–20% of patients' records were compared with registry data).; – Followup was reasonably complete for the registry purpose.
Analysis and Reporting
- The report describes the methods, including target population and selection of study subjects, compliance with applicable regulatory rules and regulations, data collection methods, any transformation of variables and/or construction of composite endpoints, how missing data were handled statistical methods for data analysis, and any circumstances that may have affected the quality or integrity of the data. The information was reported with enough detail to allow replication of the methods in another study.; - Results were reported for all the main objectives, including estimates of effect for each.; - Accepted analytic techniques were used; these may have been augmented by new or novel approaches.; - Followup time was described to enable assessment of the impact of the observation period on the conclusions drawn.; - The role and impact of missing data and potential confounding factors were considered.; - The report includes a clear statement of any conclusions drawn from the analysis of the registry's main objectives and any implications of study results. Alternative explanations for the observed results were considered; a variety of factors, including the strength of the association, biases, and temporal relations, were considered before drawing any causal inferences. The practice of making inferences about causation largely on the outcome of tests of statistical significance is discouraged.; - The consistency of results was compared and contrasted with other relevant research.

Table 25–5 Further indicators of registry evidence quality (optional)

External Validity
- Eligibility (inclusion and exclusion criteria) was confirmed on enrollment.; - Selection bias was evaluated by describing the representativeness of the actual population in terms of how it was selected how well the characteristics of the actual population match those of the target population, and to whom the results apply.
Internal Validity
- Results that can be confirmed by an unbiased observer—such as death, test results, and scores from validated measures for patient-reported results or clinical rating scales—were used to enhance accuracy and reliability.; - For safety and quality reporting (to third parties)—; – Potential sources of error relating to accuracy and falsification were rigorously evaluated and quantified to the extent feasible (e.g., through database and/or site reviews).; – Reproducibility of coding was evaluated.
Analysis and Reporting
- Validated analytic tools were used for the main analysis. For example, commercially available analytic packages were used. The data elements used in any models were described.; - Effect estimates among meaningful subgroups were described.; - Appropriate statistical techniques were used to address confounding.; - Sensitivity analyses were used to examine and quantify the effect on the association between the a priori exposure of interest and the outcome(s) by, for example, varying the definitions of exposure, potential confounders, and outcomes.; - For safety studies, the risks and/or benefits of products, devices, or processes under study were quantitatively evaluated beyond simply evaluating statistical significance (e.g., rates, proportions, and/or relative risks, as well as confidence intervals, were reported).; - For studies of comparative effectiveness and safety, contemporaneous data were collected for one or more comparison groups that reflect current clinical practice, when other reasonably accurate and relevant comparative data were not available.

Most importantly, the essential elements of good practice, as well as the optional further indicators of quality depend, to a great extent, on the resources and budget available to support registry-based research.

## References for Chapter 25

1 Gliklich RE, Dreyer NA, editors. Registries for Evaluating Patients Outcomes: A User's Guide. Rockville, MD. Agency for Healthcare Research and Quality. April. 2007.
2 Dreyer NA, Garner S. Registries for robust evidence. JAMA. Aug. 19. 2009;302(7):790-1. [pmid: 19690313].
3 Moher D, Schulz KF, Altman D, et al. The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomized trials. JAMA. Apr. 18. 2001;285(15):1987-91. [pmid: 11308435].
4 von Elm E, Altman DG, Egger M, et al. The Strengthening the Reporting of Observational Studies in Epidemiology (STROBE) statement: guidelines for reporting observational studies. Ann Intern Med. Oct. 16. 2007;147(8):573-7. [pmid: 17938396].
5 Vandenbroucke JP, von Elm E, Altman DG, et al. Strengthening the Reporting of Observational Studies in Epidemiology (STROBE): explanation and elaboration. PLoS Med. Oct. 16. 2007;4(10):e297. [pmid: 17941715].
6 Moher D, Jadad AR, Nichol G, et al. Assessing the quality of randomized controlled trials: an annotated bibliography of scales and checklists. Control Clin Trials. Feb. 1995;16(1):62-73. [pmid: 7743790].
7 Rothman K, editor. Causal inference. Chestnut Hill, MA. Epidemiology Resources, Inc. 1988.
8 Rothman K, Greenland S. Modern Epidemiology. 2nd ed. Philadelphia. Lippincott Williams & Wilkins. 1998:135-61.
9 Weiss NS. Clinical epidemiology: The study of the outcome of illness. New York. Oxford University Press. 2006.
10 Fletcher RH, Fletcher SW, Fletcher EH. Clinical epidemiology: the essentials. Baltimore, MD. Williams & Wilkins. 1996.
11 Lash TL, Fox MP, Fink AK. Applying quantitative bias analysis to epidemiologic data. New York, NY. Springer. 2009.
12 West S, King V, Carey TS, et al. Systems to Rate the Strength of Scientific Evidence. Evidence Report/Technology Assessment No. 47. (Prepared by the Research Triangle Institute-University of North Carolina Evidence-based Practice Center under Contract No. 290-97-0011). AHRQ Publication No. 02-E016. Rockville, MD. Agency for Healthcare Research and Quality. 2002. http://www.effectivehealthcare.ahrq.gov/reports/final.cfm.
13 Greenland S. Invited commentary: a critical look at some popular meta-analytic methods. Am J Epidemiol. Aug. 1. 1994;140(3):290-6. [pmid: 8030632].
14 Berkman ND, Lohr KN, Morgan LC, et al. Reliability Testing of the AHRQ EPC Approach to Grading the Strength of Evidence in Comparative Effectiveness Reviews. Methods Research Report. (Prepared by RTI International-University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-EHC067-EF. Rockville, MD. Agency for Healthcare Research and Quality. May. 2012. http://www.effectivehealthcare.ahrq.gov/reports/final.cfm.
15 National Center for the Dissemination of Disability Research. http://www.ncddr.org. August 20, 2012.
16 Mosteller F, Boruch R, editors. Evidence matters: randomized trials in education research. Washington, DC. The Brookings Institute. 2002.
17 Shavelson RJ, Towne L, editors. Scientific research in education. Washington, DC. National Research Council, National Academy Press. 2002.
18 Lohr KN. Rating the strength of scientific evidence: relevance for quality improvement programs. Int J Qual Health Care. Feb. 2004;16(1):9-18. [pmid: 15020556].
19 Ispe. Guidelines for good pharmacoepidemiology practices (GPP). Pharmacoepidemiol Drug Saf. Feb. 2008;17(2):200-8. [pmid: 17868186].
20 European Medicines Agency. ICH Topic E 6 (R1) Guideline for Good Clinical Practice. http://www.ema.europa.eu/docs/en_GB/document_library/Scientific_guideline/2009/09/WC500002874.pdf. December 26, 2013.
21 CIOMS. 1991 International Guidelines for Ethical Review of Epidemiological Studies. http://www.cioms.ch/publications/guidelines/1991_texts_of_guidelines.htm. August 20, 2012.
22 Gliklich R, Dreyer NA, Leavy MB, et al. Standards in the conduct of registry studies for patient-centered outcomes research. Prepared for the. Patient-Centered Outcomes Research Institute. Washington, DC. 2012. http://www.pcori.org/assets/Standards-in-the-Conduct-of-Registry-Studies-for-Patient-Centered-Outcomes-Research.pdf. August 21, 2012.
23 Shea BJ, Hamel C, Wells GA, et al. AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol. Oct. 2009;62(10):1013-20. [pmid: 19230606].
24 Centers for Disease C. Guidelines for evaluating surveillance systems. MMWR Morb Mortal Wkly Rep. May. 6. Suppl 5. 1988;37:1-18. [pmid: 3131659].
25 Goldberg J, Gelfand HM, Levy PS. Registry evaluation methods: a review and case study. Epidemiol Rev. 1980;2:210-20. [pmid: 7000537].
26 Stroup DF, Berlin JA, Morton SC, et al. Metaanalysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. JAMA. Apr. 19. 2000;283(15):2008-12. [pmid: 10789670].
27 Dixon WG, Carmona L, Finckh A, et al. EULAR points to consider when establishing, analysing and reporting safety data of biologics registers in rheumatology. Ann Rheum Dis. Sep. 2010;69(9):1596-602. [pmid: 20525843].
28 Equator Network. http://www.equator-network.org/library/. December 26, 2013.
29 Dreyer NA, Schneeweiss S, McNeil BJ, et al. GRACE principles: recognizing high-quality observational studies of comparative effectiveness. Am J Manag Care. Jun. 2010;16(6):467-71. [pmid: 20560690].