# Registries for Medical Devices

## 1 Introduction

Medical device registries are critical for the identification and study of medical devices outcomes. Device registries are used for many purposes, including short- and long-term surveillance, fulfillment of postmarket observational study commitments for regulatory bodies, and comparative safety and effectiveness assessments, including those in under-studied subpopulations. (See Chapter 1 for extensive discussion on the definition and purposes of registries in general.) Medical device registries play an increasingly important role in bridging the gap between device performance in clinical trials and their use in routine practice over time. Unlike clinical trials, device registries allow assessment of medical device performance in a real-world setting. Registries contain data on large numbers of patients receiving care in diverse clinical settings and include clinical outcomes over time, thus providing a critical platform for capturing the experience with a medical device throughout the device and patient lifecycle. Moreover, by linking device exposures and long-term outcomes, registries permit followup that can span decades.

While devices share some similarities with drugs, several major issues unique to devices require special consideration in order to construct and use a medical device registry successfully. Outcomes associated with medical devices can be affected not only by underlying patient factors and device factors (such as biomaterials), but also by user interface (e.g., surgical technique or surgical preference and experience) and ancillary technologies (e.g., choice of imaging). Adverse effects of devices can be localized (e.g., stent thrombosis), but may be more systemic (e.g., toxic, allergic, autoimmune effects). Furthermore, additional hazards may be related to human factor errors such as poor design or adverse interactions (e.g., drug-device or electromagnetic interference). Finally, reasons for device malfunctions may be very diverse, ranging from manufacturing problems and design-induced errors to environmental factors (e.g., humidity) and poor maintenance. Also, although certain malfunctions or device performance issues may appear to be similar, their root cause may vary.

Special challenges related to registry design, data collection, and analysis include the need for unique identification of devices, including device modifications and device components; information on user interface (e.g., surgical technique); information on ancillary technology and therapies (e.g., drug exposures); detection of device performance issues; the need for followup; and the impact of health care provider experience and learning.

This chapter will address two topics related to medical device registries: challenges in design and data collection and potential uses of emerging technology. The chapter begins with a discussion of the major considerations that influence the design of device registries and the data that must be collected. Potential approaches to address a variety of design challenges are described. The chapter then discusses emerging technologies that will potentially allow integration of automated device data capture into registry data sets. Case Examples 58, 59, 60, and 61 offer descriptions of medical device registries.

## 2 Differences Between Drugs and Devices

Regulatory oversight of the approximately 1,700 marketed device types in the United States is achieved through the use of regulatory controls and a classification process to assure reasonable device safety and effectiveness. The U.S. Food and Drug Administration (FDA) Center for Devices and Radiological Health regulates a wide range of products. These are identified into classes I, II, and III, based on the level of control necessary to ensure the safety and effectiveness of the device and the intended use and indications for use of the device. The Total Product Life Cycle1 follows products from concept to obsolescence and incorporates post-approval and surveillance information, such as rare adverse events or issues within subpopulations, back into these new product generations. This useful framework establishes a solid baseline for understanding effectiveness and safety in devices.

Differences between drugs and devices persist throughout the Total Product Life Cycle. Drug modifications occur slowly, if at all, whereas device technologies often experience rapid and continuous changes over time, potentially driven by user feedback and involving the use of new materials and approaches.2, 3 In addition, device performance is affected by factors beyond the device itself, such as operator skill and experience.4

## 3 Design and Data Collection Considerations

As with all registries, the primary purpose of a medical device registry will guide design options. Many factors related to registry design are similar to those discussed in Chapter 3, such as selection of a study design and sample size considerations. However, some distinctive features of a medical device registry require additional planning. It is critical that the registry is adaptable to various needs that arise during the lifecycle of device innovation. Some challenges include the lack of unique device identifiers, including model/version control and component identification; the need to adequately capture device malfunctions and failures; the need for longer followup; and the impact of provider experience, training, and choice of device. It is informative that some device registries have been developed from procedure registries, with the addition of device identification modules. In these cases, likely risks of device failures may be identified prior to consequential clinical signs and symptoms, allowing for device fixes before harms are experienced by the patient. This chapter will provide general suggestions for addressing these challenges, and although each device registry is unique and will require a solution appropriate for its specific purpose, general principles apply in many cases.

### 3.1 Device Identification

Currently, although Unique Device Identifiers (UDI) are available for some medical devices (in the form of GTIN or HIBC identifiers, which are numbers located under bar codes), they are not routinely captured in observational data sources like billing claims data or registries, as is the case with National Drug Codes, which permit universal drug identification. The inability to identify specific devices affects registry design and data collection and poses challenges for researchers and regulators. Compounding the problem is the fact that device modifications are frequent and part of the business model for manufacturing and innovation. Researchers may connect safety and effectiveness to a class/subset of devices, rather than to the device generally. Hence, it is critically important to identify an individual device accurately. Related challenges include the lack of standardized definitions and of attribute (descriptor) creation based on specific device product codes; difficulties in data collection, such as transmitting information from electronic medical records (EMR) to registries or automated data capture, such as those related to barcode scanning accuracy;5 and hurdles in maintaining master product lists.

Based on a congressional mandate (Section 226 of the FDA Amendments Act of 2007 and Section 614 of the FDA Safety and Innovations Act), FDA recently issued a draft rule detailing the requirements of manufacturers to have UDIs for their products, and to have this requirement phased in over several years. This FDA initiative eventually will assist with many of the challenges posed by the current lack of standard identifiers for medical devices. In the meantime, several approaches may be used to capture identity in the absence of a UDI that is unique across all devices. For example, some devices have identifiers, such as catalogue, model, serial, and lot numbers, that are unique to a particular manufacturer's device. While these are not standardized and there may be several components from different manufacturers with similar catalogue or model numbers, these numbers can facilitate device identification and tracking when combined.

Thus, prior to full UDI adoption and implementation, researchers must be creative in collecting device information and taking advantage of UDI-like data to fill the gap created by the lack of identifiers. For example, the Society of Thoracic Surgeons Adult Cardiac Database developed a data collection form with an exhaustive list of various heart valve devices. This checklist enables registry participants to collect any information that could be relevant to their practice. Orthopedic registries worldwide are taking advantage of catalogue numbers and lot or serial numbers in order to classify and uniquely identify products. An inefficient but at times appropriate solution is to include device photos in the registry. This strategy is most applicable in settings with few devices on the market that have marked differences in design that can be captured with photographs.

### 3.2 Device Performance

Devices exhibit numerous types of performance issues, so that it is difficult to capture all potential performance issues, failure modes, and adverse events in a single device registry. The performance issues may be related to software, hardware, biomaterials, sterility, or other issues. Additionally, similar performance problems (e.g., pacemaker oversensing) could have various root causes, some of which may manifest clinically (e.g., breast implant rupture) while others may not. Importantly, although clinical trials may provide some knowledge of failure rates and timing, knowledge of the propensity of these failures to develop is limited during the registry design phase. Adverse-event reporting for device registries should follow the regulatory requirements for reporting.6 Researchers should consider methods of adjudication and verification of issues with device performance during the design phase in order to ensure collection of all data elements needed to inform those discussions. It is also important to consider how potential performance issues will be detected for the particular device.

Automated surveillance within the registry is an advanced approach to identifying select performance issues with a device (i.e., those that manifest uniquely and clinically). When implemented correctly, it can permit real-time evaluation of performance issues within a large sample or population. Surveillance, however, is a complex endeavor, and standardized data elements and collection procedures are required, likely across multiple institutions or registries. There are several examples of successful registry implementation for surveillance in cardiovascular disease. The Data Extraction and Longitudinal Trend Analysis (DELTA) network study was the first computerized safety surveillance proof-of-concept study for cardiovascular medical devices. This multicenter prospective observational study was designed for safety evaluation of drug-eluting coronary stents, embolic protection devices, and vascular closure devices used during percutaneous coronary intervention.7 The study facilitated aggregation of safety events across institutions by using standard data elements from the American College of Cardiology National Cardiovascular Data Registry (NCDR^®^).

### 3.3 Device Systems and Components

In many cases, the device of interest for a registry is either part of a larger system of devices or contains multiple components that are considered devices themselves. Issues around the lack of unique identifiers persist and are accompanied by the additional challenge of determining which component is responsible for the performance issues. Sometimes, FDA approves or clears device components separately. When a registry is designed to understand effectiveness and safety, and the device of interest is dependent on accompanying devices included in the same system, information on all components must ideally be captured in enough detail to assess how well the device of interest is functioning.

In some instances, FDA approves devices as full systems rather than singular components. Examples of this include implantable pacemakers, implantable cardioverter defibrillators, and hip and knee implants. In these cases, surgeons may “mix and match” multiple manufacturers or multiple brands into one system. Such mixing presents a data collection issue as well as an analytical challenge. Heterogeneous devices may need to be grouped together in order to perform analysis.

In addition to the actual device, some implantable devices require assistance from procedural devices, including other commodity devices or operative instruments, or ancillary devices, such as imaging equipment. In these cases, clinically relevant additional information should be collected. For example, in hernia repair, information on the method of mesh adhesion, such as staples, glue, or sutures, may need to be collected, as these adhesives could interact with a specific type of mesh and affect device performance. Researchers should consider the role of these factors and how they can be captured in the data collection process.

### 3.4 Drug/Device Combinations

Device/drug combinations have become increasingly common over the past decade. Because the development processes for drugs and devices differ, combination products face different challenges. For example, drug-eluting stents (DES) are an example of a product where the device, a bare-metal stent, has been enhanced by the addition of an immunosuppressant or mitotic inhibitor8 and its elution polymer coating. In 2003, FDA approved the addition of drugs to stents for a subset of cardiac patients with uncomplicated coronary lesions.9 In these patients, there was a decrease in coronary restenosis requiring repeat revascularization 9 months after stent implantation, compared with bare-metal stents. However, as the adoption rate of DES increased, the population of patients in which they were implanted changed—they tended be sicker patients. Moreover, stent thrombosis, a rare but serious adverse event, was higher in DES patients at 1 year compared with bare-metal stent patients.10-12 Stent thrombosis represented a localized device failure mode with serious and unique clinical manifestations. In cases like this, registries are a critical tool for understanding the long-term safety and effectiveness of the technology.13, 14 Special considerations in registry design include separate collection of concomitant drug dosing information and attention to the medications that the patient is taking during and post implantation in order to flag possible drug interactions. It is also important to prospectively collect concurrent medications that the patient is using over time, again in order to understand potential interactions.

### 3.5 Obtaining Sufficient Followup Information

Obtaining sufficient followup information and as complete as possible case ascertainment are issues for all studies, and many of these challenges are addressed in Chapters 3 and 10. However, long-term followup is a particular concern with implantable devices, as well as other products such as ablation and radiation therapy devices. Clinical trials have relatively short followup for implantable devices that are expected to stay in the body indefinitely or until replaced with a similar device. These devices are typically studied for less than 5 years premarket, but are intended to work for decades. While followup time in the initial period of implantation is useful, an indefinite followup registry imbedded within a clinical practice has the ability to answer questions concerning device safety and effectiveness over the full product lifecycle. Only a few registries have sufficient followup for endpoints of device performance, continuous effectiveness, and safety. One of the best examples is Australia's National Joint Replacement Registry,15 which has followup of more than 10 years.

A unique challenge for device registries is that once a device is implanted, a patient does not have to return to the doctor if he or she does not have any issues, in contrast to a therapeutic situation in which patients return for prescription refills. As a result, collecting followup data both directly from patients and through the health care provider is a useful tool for patient retention. Loss to followup differentially for patients who do not experience complications is a risk, and underscores the importance of achieving reasonably complete followup on all patients through delivery settings well designed for continuity of care.16 Long-term data on medical devices also can be obtained through linking registries with administrative billing data, electronic health records, or other clinically rich data sources, although data limitations such as lack of test results or reasons for procedures may remain.

### 3.6 Provider Experience and Training

Provider experience and training can influence the selection of device, device performance, and patient outcomes, particularly for implantable devices. Surgeons generally have a preference in terms of selection of devices, and although sometimes this preference is based on clinical appropriateness, it also can be based on marketing or familiarity with a particular brand. Group purchasing organizations, cost, provider contracts, reimbursement, and other market forces may also influence selection and, in some of these cases, surgeons may not have a choice of device. Additionally, provider experience and surgical/procedural skill can greatly influence the effectiveness and safety of devices.17

Device-specific training is an important element of a medical device registry that is not an issue in a drug registry. Device premarket studies are typically smaller than drug studies. Post-approval, regulatory agencies are concerned about training program quality. Often, an observational study is required to formally evaluate the appropriateness of physician training. Regardless of whether regulators have mandated this type of study, they recommend integrating training information into data collection. The importance of this training varies based on device type. For example, physicians with experience using balloon-expandable or self-expanding stents may not need additional device-specific training to use a new carotid stent. In contrast, prior experience may not be translatable to use of a new percutaneous valve; in this case, specific training on the delivery technique required for that specific valve is important. The amount of training required to ensure safe application of a technology is often unclear.9

Experience-related factors also should be considered in analyses and training evaluation: practitioner annual volume; practitioner lifetime volume; facility volume; and facility characteristics such as academic teaching status. It is important to distinguish between these factors because each has a threshold effect. Some factors, particularly lifetime volume, have not been well documented or analyzed. For others, such as hospital volume and academic teaching status, relationships with complications, revision surgery, length of hospital stay, and mortality are well documented.18-20 It is ideal to have training and volume information in the registry, but this may not always be realistic. If this is deemed critical, information needs to be collected on provider experience and training at registry initiation and supplemented if any training programs occur during the registry development.

Registry design teams should consider how provider training and learning curves can be handled during analysis. Particularly for devices with few qualified surgeons, clustering may be an issue in analysis. Sample size may need to increase, and statistical methods that account for clustering, such as generalized estimating equations, should be used. Adjustment by surgical volume, either on the hospital or provider level, might also be appropriate.21 For example, some studies have shown that categories integrating both of these components as one adjustment variable (e.g., high-volume hospital and surgeon; high-volume hospital with low-volume surgeon; low-volume hospital with high-volume surgeon; both low volume) are useful.22

### 3.7 Summary of Design and Data Collection Considerations

Although device registries are similar to other registries operationally, the challenges outlined above are critical to consider during the registry design phase. Careful review of the unique features of medical device registries can result in high-quality, useful studies of device performance. Medical devices must be identified accurately and their attributes classified according to standard nomenclature. Minimum recommended identity variables include manufacturer, product name, lot number (where applicable), catalog number, serial number (where applicable and with appropriate consideration for protected health information), description of device, and device attributes. These implant characteristics can then be linked to patient, surgeon, hospital, and procedural data along with outcomes of interest. For these reasons, diligence in information security is warranted when identity variables are being collected, and these data should not be included in limited data sets. (See Chapter 7 for a full discussion of the implications of collecting individually identifiable data within a patient registry.) Device identification and attribute classification require constant maintenance as new devices are introduced into the market. In the future, UDIs will significantly facilitate this process. A standard minimum data set targeted toward device registries would be useful to support strong registry designs and to facilitate linkages with other data sources.

The definition and validity of device performance issues is another important element. In developing a device registry, the modes of failures and definitions must be clearly defined. Pragmatic systems for outcome verification need to be in place. It is also crucial to track all device components in case a single component fails. Collecting information to track drug/device interactions is also critical. Finally, sufficient followup of patients must be established in order for registries to provide longitudinal outcomes.

## 4 Regulatory Uses and Considerations

FDA has for a long time been actively engaged in the use and development of registries for both pre- and postmarket assessments of device safety and effectiveness. For premarket considerations, device registries have: (1) provided data to support the development, design, and use of comparators (both concurrent and historical) in clinical trials (e.g., the National Heart, Lung, and Blood Institute's (NHLBI) Interagency Registry for Mechanically Assisted Circulatory Support [INTERMACS™ ], heart valves); (2) provided access to products (outside of IDE [investigational device exemption] trials) (e.g., PFO [patent foramen ovale] occluders); (3) enhanced safety assessments via broader analysis of adverse events (e.g., adhesion barriers); and (4) expedited approval of device modifications or labeling (e.g., intraocular lenses). Postmarket applications of device registries have included frequent use in FDA-mandated studies (e.g., drug-eluting coronary stents), use in enhanced passive surveillance efforts (e.g., INTERMACS; the Department of Veterans Affairs' Clinical Assessment, Reporting, and Tracking System for Cardiac Catherization [CART-CL]), use in exploratory efforts to expand FDA Sentinel capabilities, both in active surveillance and data source linkage (e.g., DELTA), and use in discretionary applied research as noted below.

Over time, various stakeholder communities have increased their efforts to foster the development of clinical registries as a valuable postmarket tool for capturing utilization of devices, identifying early signals, and studying postmarket performance of medical technology. Some of these efforts transformed what were primarily procedure registries into procedure/device registries for certain targeted devices of interest. Examples of longstanding collaborative efforts include those between FDA and professional society databases such as the American College of Cardiology NCDR.23 This collaboration resulted in one of the largest observational studies on hemostasis devices using NCDR registry data.24 In addition, FDA collaborated with Duke University and the Society of Thoracic Surgeons to study the outcomes of transmyocardial revascularization procedures using the Adult Cardiac Surgery Database.25 More recently, the national multistakeholder community, including professional societies, FDA, and the Centers for Medicare and Medicaid Services, worked together to establish the first national transcatheter valve therapy (TVT) registry to capture transcathether aortic valve replacement therapies.26 This effort aims to foster both pre- and postmarket uses for future TVT devices and indications. In the orthopedic arena, FDA led the development of the International Consortium of Orthopedic Registries to advance the methodological infrastructure for studying performance and clinical outcomes of orthopedic implants.27

FDA continues to foster the development of registries in key product areas. It also recognizes the need for a national perspective on device registry development that considers how best to: (1) leverage existing experience and expertise; (2) establish common data elements across registries; (3) share evolving methodological tools; (4) enhance interoperability between standard electronic health records and registries; (5) create sustainable business models; and (6) adopt robust and transparent governance practices.

## 5 Potential Uses of Emerging Technology

Registries may soon be able to take advantage of emerging technology for data transmission. New technologies can enable medical devices to transmit data directly to electronic medical records and other patient management systems. Ultimately, this type of data may be sent directly to a patient registry, reducing the burden of data entry and increasing the timeliness of registry data.

These new technologies are currently at various stages of development. Automatic measurement and adjustment of programming to provide optimal settings is a potential area of innovation that would provide efficiencies in the use of pacemakers and other implantable devices. Feasibility for this has been demonstrated by the AUTOMATICITY registry, which aims to evaluate physicians' acceptance of automatic algorithms for ventricular capture, automatic sensing, and automatic optimization of sensor settings.28, 29 The AUTOMATICITY team concluded that project team followup and avoidance of reprogramming due to the automated programming can increase effective use of hospital time and resources. This would be a useful technology for registries because all automated changes can be collected at one followup time point, rather than collecting each change ad hoc as it occurs.

Diagnostics for implantable devices are another area of technical improvement. Implantable devices, such as implantable cardioverter defibrillators, pacemakers, and cardiac resynchronization therapy devices, can track heart rate, heart rate variability, respiration rate, atrial tachyarrhythmia and ventricular tachyarrhythmia recurrence and duration, intrathoracic impedance, symptom markers, and patient activity.30 This diagnostic information can be provided directly to EMRs and fed into registries, in many cases continuously. Although the clinical application of this capability is still being examined, the benefits in efficient, timely data capture are clear.

The fascinating pace of emerging medical technologies and information science applications are expected to further shape health care research. Further development and integration of device-based registries into the national postmarket infrastructure creates opportunities for novel methodology developments, harmonization, sharing, and combining of data.

## 6 Summary

Medical device registries can be designed for a variety of purposes. They can provide useful information on long-term effectiveness and safety of devices, as well as the impact of factors such as surgical technique, surgeon, hospital, and patient characteristics. Like all observational studies, medical device registries have some limitations. Failure to control for often complex confounding variables and the inability to take into account device version changes, surgical technique, and other unique factors can lead to erroneous conclusions. However, design and analysis of medical device registries can often provide critical information for decisionmaking by regulators, clinicians, patients, and policymakers.

## Case Examples for Chapter 23

Case Example 58 Designing a registry to study the effectiveness of a device training program for providers

Description | The Carotid Artery Stenting with Emboli Protection Surveillance Post-Marketing Study (CASES-PMS) was designed to assess the outcomes of carotid artery stent procedures for the treatment of obstructive artery disease during real-world use. The primary purpose of the registry was to evaluate outcomes in the periapproval setting, including the use of a detailed training program for physicians not experienced in carotid artery stenting.
Sponsor | Cordis Corporation
Year Started | 2004
Year Ended | 2006
No. of Sites | 74
No. of Patients | 1,493

#### Challenge

In 2004, the sponsor received approval for a carotid stent procedure from the U.S. Food and Drug Administration (FDA), largely because of the results of the Stenting and Angioplasty With Protection in Patients at HIgh Risk for Endarterectomy (SAPPHIRE) clinical trial. The SAPPHIRE trial studied the results of stent procedures performed by experts in the field. While the trial provided strong data to support the approval of the carotid stent, FDA and the Centers for Medicare & Medicaid Services (CMS) both questioned whether the outcomes of the trial were generalizable to procedures performed by physicians without prior experience in carotid artery stenting.

To respond to the FDA and CMS requests, the sponsor needed to design a study to confirm the safety and effectiveness of carotid artery stenting in a variety of settings. The study needed to gather data from academic and nonacademic settings, from physicians with various levels of carotid stenting experience, from settings with varying levels of carotid stenting volume, and from a geographically diverse mix of sites. The study would also need to examine the effectiveness of a training program that the sponsor had designed to teach physicians about the stenting procedure.

#### Proposed Solution

The sponsor designed a comprehensive training program for physicians and other health care professionals. The training program, which began in 2004, included didactic review, case observations and simulation training, and hands-on experience. Depending on their prior experience with carotid artery stenting, physicians received a 2-day in-person training plus online training; online training only; or no additional training. To study the effectiveness of the training program and to provide data on the clinical safety and effectiveness of carotid stenting in a variety of settings, the sponsor designed and launched the registry in 2004.

The registry was a multicenter, prospective, observational study designed to assess stenting outcomes in relation to the outcomes of the SAPPHIRE trial (the historic comparison group). The study enrolled 1,493 patients from 74 sites, using inclusion and exclusion criteria that matched those of the SAPPHIRE trial. The patients in the study were high-surgical-risk patients with de novo atherosclerotic or postendarterectomy restenotic obstructive lesions in native carotid arteries. Study participants completed clinical followups at 30 days and again at 1 year after the procedure. The 30-day assessments included a neurological examination by an independent neurologist and an evaluation of adverse events. The study defined the 30-day major adverse event rate as the 30-day composite of all deaths, myocardial infarctions, and strokes.

#### Results

The 30-day major adverse event rate of 5.0 percent met the criteria for noninferiority to the outcomes of stented patients from the pivotal SAPPHIRE trial. Outcomes were similar across levels of physician experience, carotid stent volume, geographic location, and presence/absence of the training program. The initial findings show that a comprehensive, formal training program in carotid stenting enables physicians from multiple specialties with varying levels of experience in carotid stenting to achieve outcomes similar to those achieved by the experts in the clinical trial.

#### Key Point

An observational registry can provide the necessary data for a postmarket evaluation of devices that are dependent on newly acquired skills. The registry can provide data to assess both the clinical safety of the device and the effectiveness and success of a training program.

#### For More Information

Katzen B, Criado F, Ramee S, et al., on behalf of the CASES-PMS Investigators. Carotid artery stenting with emboli protection surveillance study: 30-day results of the CASES-PMS study. Catheter Cardiovasc Interv. 2007;70:316-23. [pmid: 17630678]. .

Yadav JS, Wholey MH, Kuntz RE, et al. Protected carotid-artery stenting versus endarterectomy in high-risk patients. N Engl J Med. 2004;351:1493-501. [pmid: 15470212]. .

Case Example 59 Identifying and responding to adverse events found in a registry database

Description | The Kaiser Permanente National Total Joint Replacement Registry (TJRR) was developed by orthopedic surgeons to improve patient safety and quality and to support research activities. The TJRR tracks all Kaiser Foundation Health Plan members undergoing elective primary and revision total knee and hip replacement. The purposes of the registry are to (1) monitor revision, failure, and rates of key complications; (2) identify patients at risk for complications and failures; (3) identify the most effective techniques and implant devices; (4) track implant usage; and (5) monitor and support implant recalls and advisories in cooperation with the U.S. Food and Drug Administration. The TJRR uses an electronic medical record (EMR) system to collect uniform data at the point of care. Data are abstracted from the EMR to the registry, and followup data are collected through several methods.
Sponsor | Kaiser Foundation Health Plan
Year Started | 2001
Year Ended | Ongoing
No. of Sites | 350 surgeons at 50 medical centers
No. of Patients | 140,000 total joint replacements

#### Challenge

The registry collects standardized total joint preoperative, operative, and postoperative data to supplement administrative data collected through the EMR. The registry database includes information on patient demographics, implant characteristics, surgical techniques, and outcomes. As a result, the registry provides opportunities for total joint replacement surveillance and monitoring, but the depth and breadth of the data make manual data reviews for adverse events (AEs) too resource intensive and time consuming.

#### Proposed Solution

Electronic screening algorithms were developed to detect AEs in the registry database in a timely, efficient manner. The algorithms use ICD-9 codes and CPT codes to identify complications of joint replacement surgery, such as revisions, reoperations, infection, and pulmonary embolism. All complications picked up by the screening algorithms are validated with a chart review. The screening algorithms are run and the results monitored on a regular basis to identify trends.

The registry can also run specific queries to respond to physician concerns. For example, if physicians at participating medical centers notice a problem with an implant or hear about a problem from colleagues, they can request an ad hoc query of the registry database. The query can identify all patients receiving a particular implant and assess outcomes. When the outcome of interest is not part of the registry database, the registry staff may perform additional followup through chart review. The staff may also check the U.S. Food and Drug Administration's Medical Product Surveillance Network (MedSun) to validate their findings against other data sources.

Once an implant has been recalled or when there is an advisory or concern, the registry can immediately generate a list of all patients who received that implant and notify their physicians. The registry can also identify complications and assess revision rates among its patients who received that implant. Registry staff continue to monitor outcomes of patients who undergo revision surgery, until the patient dies or is lost to followup.

#### Results

Since its launch in 2001, the registry has assisted participating physicians with their responses to several implant recalls and advisories. Data from the registry were used to identify surgical techniques that resulted in higher revision rates. The registry staff shared this information with physicians, resulting in reduced use of these techniques.

#### Key Point

Electronic screening algorithms offer an efficient method of identifying potential AEs in large data sets in a timely manner. For such algorithms to be effective, the registry database must collect detailed information on the implants' lots and catalog numbers, and must be updated frequently as new and modified products become available. In addition, when using medical codes, it is important to validate the results of the screening algorithm to ensure that coding errors have not affected the findings.

Case Example 60 Receiving data from medical imaging devices

Description | The Dose Index Registry collects data on radiation doses administered during computed tomography (CT) examinations. Facilities can compare their average radiation dose for a particular examination (e.g., CT head examination) to that of similar facilities and to the national average. Such comparisons help facilities identify examinations for which their dose indices may be higher than others and adjust their protocols accordingly. Because it does not collect patient outcomes, the registry is considered a registration registry rather than a patient registry. The example is presented to illustrate the ability to use medical devices to report information directly to registries or other databases.
Sponsor | American College of Radiology
Year Started | 2011
Year Ended | Ongoing
No. of Sites | Over 200
No. of Patients | Over 1,000,000 CT examinations

#### Challenge

Safety concerns over the effects of ionizing radiation exposure from diagnostic imaging have been described in numerous publications and summarized in a Joint Commission Sentinel Event Alert posted August 24, 2011 (Issue 47). To address some of these concerns, the American College of Cardiology established the Dose Index Registry to collect and compare data on radiation doses administered during CT examinations.

For the data collection system to be a viable tool for participating facilities, it was imperative that the data be collected without interrupting the workflow at the facility (i.e., without adding additional workload for the CT technologist). The biggest challenge facing the registry was to automate and standardize the collection of dose information provided by several CT manufacturers in a variety of formats.

#### Proposed Solution

The sponsor worked with the organization Integrating the Healthcare Enterprise to develop the Radiation Exposure Monitoring (REM) profile. This profile describes the way dose information should be transmitted across different health care settings and specifies that information should be transmitted to a registry in the form of a Radiation Dose Structured Report (RDSR). However, only the most recent versions of CT scanner models and software support RDSR. In order to accept dose information provided by older scanners, the registry developed software that could convert the data into the RDSR format. The software that collects dose information also removes patient identifiers before sending data to the registry.

The second hurdle in standardization was the development of a common nomenclature for CT examinations. Different names are used for the same examination both within and among imaging facilities, and the registry needed a standard terminology for meaningful reporting. While it would have been possible to develop a new standard, the registry was aware of other lexicons under development, such as the Radlex Playbook. Conversations between the registry and the Radlex Playbook developers allowed the two groups to understand and meet each other's needs, and the registry was able to adopt the Radlex Playbook as the standard terminology for exam names. For facilities that submit data using non-standard terminology, these terms are mapped to Radlex Playbook terminology using a mapping tool developed by the registry.

#### Results

To date, the data collection system has collected information related to CT radiation dose from over 200 facilities nationwide and has collected dose information from over 1,000,000 CT examinations. In addition to allowing comparison of dose indices between facilities, data collected from the registry will also be used to establish national benchmarks for CT dose indices.

#### Key Point

While not a patient registry, this example demonstrates that registries that collect information from medical devices may be able to reduce data entry burden by incorporating data transmitted directly from the device. When considering this option, registries may benefit from communicating with industry to find solutions that are not manufacturer specific and that can be implemented within a reasonable timeframe. Registries may also benefit from working with existing standards to determine if they can be modified to fit the registry's use case.

#### For More Information

http://nrdr.acr.org

Case Example 61 Combining registry data with EHR data to measure real-world outcomes of implantable devices

Description | Members of the Cardiovascular Research Network (CVRN) are conducting a longitudinal study of the characteristics, clinical outcomes, resource utilization, and costs among “real-world” patients receiving implantable cardioverter defibrillators(ICDs) for primary prevention of sudden cardiac death.
Sponsors | National Heart, Lung, and Blood Institute (NHLBI), Agency for Healthcare Research and Quality (AHRQ), American College of Cardiology Foundation, Heart Rhythm Society
Year Started | 2009
Year Ended | Ongoing (planned completion of outcome ascertainment in 2013)
No. of Sites | Seven health care systems, with 15 participating hospital partners
No. of Patients | 3,600

#### Challenge

ICDs have revolutionized the approach to treatment for hundreds of thousands of patients in the United States with left ventricular systolic dysfunction who are at risk for sudden cardiac death. Despite broadened indications for ICD therapy, use varies across patient subgroups. Most existing data on complication rates, mortality, morbidity, and cost of primary prevention ICD therapy come from clinical trial samples, which enroll subjects who may not be representative of patients cared for in routine practice. Baseline data on patients and devices are available in the National Cardiovascular Data Registry's (NCDR) ICD Registry, but longitudinal outcomes are not routinely included in the registry system. Evaluation of longitudinal, real-world data is needed, but following large groups of patients in community care settings can present logistical challenges.

#### Proposed Solution

CVRN is a national research collaborative funded by NHLBI that leverages expertise, populations, and data sources from a consortium of 14 health plans in the United States. Seven sites in the CVRN are sponsored by NHLBI, AHRQ, the American College of Cardiology Foundation, and the Heart Rhythm Society to conduct a longitudinal study of patients receiving ICDs for primary prevention of sudden cardiac death. The aims of the study are to (1) evaluate the extent to which patients receiving ICDs for primary prevention meet guideline-based eligibility case criteria; (2) assess longitudinal outcomes, including complications, hospitalization, mortality, and delivery of device therapies among primary prevention ICD patients; and (3) identify the characteristics associated with these outcomes in real-world community practice. To achieve these goals, the study developed a new database, which links a national device registry with information from health system medical records archived in electronic and other forms.

Baseline information is obtained from the NCDR ICD Registry, which captures national data on primary-prevention ICD implants for Medicare beneficiaries, although most participating hospitals, including the study facilities, submit data to the registry for all ICD recipients regardless of insurance status. Clinical and administrative followup data for three years post-implant are collected through the electronic health record (EHR) systems of the health plans participating in the CVRN. Finally, a new repository of arrhythmic episodes treated by ICD is being generated through review and abstraction of archived device followup records at the study sites.

ICD patients have periodic followup visits which include downloading data from their devices; this data can include the number and type of arrhythmic episodes detected by the device since the last check, what therapy (e.g., shock) was administered by the device, and the outcome of that therapy. The health systems download the device data from patients during an office visit or via remote transmission over the telephone. The device followup data are then incorporated into the health system medical record archives. Since the study includes devices from a variety of manufacturers and includes device followup records in a variety of formats, study staff have created a standardized format for collecting therapy data so they can be adjudicated and analyzed. All three data sources are then combined into a single analytic data set for addressing the study's specific aims, using a unique subject identifier to link all data elements together for the same subject.

#### Results

The study includes 3,600 subjects with primary-prevention ICDs implanted from 2006 through 2010. Data collection began in 2009. A report on the study methods and the baseline characteristics of the study population has been published, demonstrating that important demographic and clinical characteristics of patients receiving ICDs in real-world clinical practice are significantly different from the population enrolled in the landmark clinical trials conducted on ICDs in the early 2000s.

#### Key Point

Existing registries and EHR data can be valuable data sources for measuring the long-term outcomes of devices in real-world settings. This is especially true for implantable devices, where data may be downloaded automatically from the device to an EHR system.

#### For More Information

Go AS, Magid DJ, Wells B, et al. The Cardiovascular Research Network: a new paradigm for cardiovascular quality and outcomes research. Circ Cardiovasc Qual Outcomes. Nov. 2008;1(2):138-47. [pmid: 20031802]. .

Masoudi FA, Go AS, Magid DJ, et al. The Longitudinal Study of Implantable Cardioverter Defibrillators: methods and clinical characteristics of patients receiving implantable cardioverter defibrillators for primary prevention in contemporary practice. Circ Cardiovasc Qual Outcomes. Nov. 2012;5(6):e78-85. [pmid: 23170006]. .

## References for Chapter 23

1 U.S. Food and Drug Administration. Total Product Life Cycle. http://www.fda.gov/AboutFDA/CentersOffices/OfficeofMedicalProductsandTobacco/CDRH/CDRHTransparency/ucm199906.htm. August 6, 2012.
2 Boam AB. Innovative Systems for Delivery of Drugs and Biologics. PowerPoint Presentation. http://www.fda.gov/ohrms/dockets/dockets/03n0203/03n-0203-ts00010-Boam.ppt. August 6, 2012.
3 Institute of Medicine. New Medical Devices: Invention, Development, and Use. Washington, DC. National Academies Press. 1988.
4 Sedrakyan A, Marinac-Dabic D, Normand SL, et al. A framework for evidence evaluation and methodological issues in implantable device studies. Med Care. Jun. 2010;48(6 Suppl):S121-8. [pmid: 20421824].
5 Paxton E. Kaiser Permanente Implant Registries. PowerPoint Presentation. http://www.fda.gov/downloads/MedicalDevices/NewsEvents/WorkshopsConferences/UCM272080.pdf. August 6, 2012.
6 U.S. Food and Drug Administration. Medical Device Report (MDR) Forms and Instructions. http://www.fda.gov/MedicalDevices/Safety/ReportaProblem/FormsandInstructions/default.htm. February 20, 2013.
7 Vidi VD, Matheny ME, Donnelly S, et al. An evaluation of a distributed medical device safety surveillance system: the DELTA network study. Contemp Clin Trials. May. 2011;32(3):309-17. [pmid: 21356331].
8 Daemen J, Wenaweser P, Tsuchida K, et al. Early and late coronary stent thrombosis of sirolimus-eluting and paclitaxel-eluting stents in routine clinical practice: data from a large two-institutional cohort study. Lancet. Feb. 24. 2007;369(9562):667-78. [pmid: 17321312].
9 Serruys PW, Kutryk MJ, Ong AT. Coronary-artery stents. N Engl J Med. Feb. 2. 2006;354(5):483-95. [pmid: 16452560].
10 Camenzind E, Steg PG, Wijns W. Stent thrombosis late after implantation of first-generation drug-eluting stents: a cause for concern. Circulation. Mar. 20. 2007;115(11):1440-55. discussion 55. [pmid: 17344324].
11 Bavry AA, Kumbhani DJ, Helton TJ, et al. What is the risk of stent thrombosis associated with the use of paclitaxel-eluting stents for percutaneous coronary intervention?: a meta-analysis. J Am Coll Cardiol. Mar. 15. 2005;45(6):941-6. [pmid: 15766833].
12 Babapulle MN, Joseph L, Belisle P, et al. A hierarchical Bayesian meta-analysis of randomised clinical trials of drug-eluting stents. Lancet. Aug. 14-20. 2004;364(9434):583-91. [pmid: 15313358].
13 Urban P, Gershlick AH, Guagliumi G, et al. Safety of Coronary Sirolimus-Eluting Stents in Daily Clinical Practice: One-Year Follow-Up of the e-Cypher Registry. Circulation. 2006;113:1434-41. [pmid: 16534015].
14 O'Malley AJ, Normand SL, Kuntz RE. Application of models for multivariate mixed outcomes to medical device trials: coronary artery stenting. Stat Med. Jan. 30. 2003;22(2):313-36. [pmid: 12520564].
15 National Joint Replacement Registry. https://aoanjrr.dmac.adelaide.edu.au/en. December 20, 2013.
16 Kuntz RE, Keaney KM, Senerchia C, et al. A predictive method for estimating the late angiographic results of coronary intervention despite incomplete ascertainment. Circulation. Mar. 1993;87(3):815-30. [pmid: 8443902].
17 Barker FG 2nd, Amin-Hanjani S, Butler WE, et al. In-hospital mortality and morbidity after surgical treatment of unruptured intracranial aneurysms in the United States, 1996-2000: the effect of hospital and surgeon volume. Neurosurgery. May. 2003;52(5):995-1007. discussion 1007-9. [pmid: 12699540].
18 Hannan EL, Racz M, Ryan TJ, et al. Coronary angioplasty volume-outcome relationships for hospitals and cardiologists. JAMA. Mar. 19. 1997;277(11):892-8. [pmid: 9062327].
19 Birkmeyer JD, Stukel TA, Siewers AE, et al. Surgeon volume and operative mortality in the United States. N Engl J Med. Nov. 27. 2003;349(22):2117-27. [pmid: 14645640].
20 Halm EA, Lee C, Chassin MR. Is volume related to outcome in health care? A systematic review and methodologic critique of the literature. Ann Intern Med. Sep. 17. 2002;137(6):511-20. [pmid: 12230353].
21 Kuntz RE, Normand SL. Measuring percutaneous coronary intervention quality by simple case volume. Circulation. Aug. 23. 2005;112(8):1088-91. [pmid: 16116067].
22 Birkmeyer JD, Siewers AE, Finlayson EV, et al. Hospital volume and surgical mortality in the United States. N Engl J Med. Apr. 11. 2002;346(15):1128-37. [pmid: 11948273].
23 National Cardiovascular Data Registry. http://www.ncdr.com. August 20, 2012.
24 Tavris DR, Dey S, Albrecht-Gallauresi B, et al. Risk of local adverse events following cardiac catheterization by hemostasis device use - phase II. J Invasive Cardiol. Dec. 2005;17(12):644-50. [pmid: 16327045].
25 Tavris DR, Brennan JM, Sedrakyan A, et al. Long-term outcomes after transmyocardial revascularization. Ann Thorac Surg. Nov. 2012;94(5):1500-8. [pmid: 22835557].
26 STS/ACC TVT Registry. https://www.ncdr.com/TVT/Home/Default.aspx. August 20, 2012.
27 Sedrakyan A, Paxton EW, Phillips C, et al. The International Consortium of Orthopaedic Registries: overview and summary. J Bone Joint Surg Am. Dec. 21. Suppl 3. 2011;93:1-12. [pmid: 22262417].
28 Alings M, Vorstenbosch JM, Reeve H. Automaticity: design of a registry to assess long-term acceptance and clinical impact of Automatic Algorithms in Insignia pacemakers. Europace. Mar. 2009;11(3):370-3. [pmid: 19240111].
29 Alings M, Vireca E, Bastian D, et al. Clinical use of automatic pacemaker algorithms: results of the AUTOMATICITY registry. Europace. Jul. 2011;13(7):976-83. [pmid: 21422022].
30 Andriulli J. Device monitoring of intrathoracic impedance: clinical observations from a patient registry. Am J Cardiol. May. 21. 2007;99(10A):23G-8G. [pmid: 17512419].