# Pregnancy Registries

## 1 Introduction

A pregnancy exposure registry is an observational prospective cohort of women receiving a biopharmaceutical product(s) of interest as part of their routine clinical care who are enrolled voluntarily during gestation, before outcomes can be known. Participants are followed until the end of pregnancy or longer to systematically collect information on specific pregnancy outcomes and evaluate their frequency relative to a scientifically valid reference population(s).1-3 Specific examples of pregnancy registries can be found on the Food and Drug Administration (FDA) Web site.4

This chapter reviews the “why, how, and who” of conducting pregnancy registries. In it we first discuss why pregnancy registries are needed to assess risks and benefits of medications during pregnancy. Second, we describe the distinctive methodological aspects of these registries, including design, study population, enrollment and followup of pregnant women, ascertainment and definition of exposures and outcomes, reference groups, statistical power, and validity issues. Third, we take a more pragmatic approach and present key operational aspects such as protocol structure, recruitment and retention of participants, methods of data collection, timing of the release of findings, role of advisory boards, and challenges of global designs. Finally, we describe characteristics to consider when evaluating pregnancy registries. Case Examples 49, 50, 51, and 52 offer some descriptions of pregnancy registries.

## 2 Justification

All patients in need of treatment should have access to medications that have been adequately studied, and they should be given information to assess risks versus benefits of using the medication. Collecting postmarketing data on the safety of medications during pregnancy is commonly done through the use of pregnancy exposure registries or pregnancy disease registries that collect treatment information. Pregnancy registries are prospective observational studies specifically designed to collect clinically relevant data and provide information for treating or counseling not only women who are pregnant but also women of childbearing potential. In 2002, FDA published its guidance for pregnancy registries2 with a goal of encouraging the regular use of more formal, prospective study designs to obtain clinically relevant human data that can be used in product labeling. Similar guidelines were published by the European Medicines Agency in 2005.^5^ In 2007, the Food and Drug Amendments Act provided the authority under Title IX6 to require pregnancy registries as a postmarketing requirement. Pregnancy registries are now required at the time of a new drug approval when there is a safety concern or when there is a need to gather data on the use of the product in pregnancy based on the following circumstances: (1) prior knowledge of the product suggests a safety concern based on the pharmacologic or chemical class, or on data from animal studies or clinical trials; (2) the product will be indicated for use during pregnancy (e.g., vaccines and medications for chronic illness); or (3) there is a high likelihood of use in females of reproductive age such that inadvertent exposure during pregnancy may be expected.

For nonpregnant individuals, safety and efficacy data that yield such information are derived from well-controlled clinical trials conducted prior to a drug's approval. When it comes to pregnant women, however, the situation is different. Clinical trials rarely include pregnant women because there is a lack of safety information on the drug's use in pregnancy.7, 8 As a consequence, most information regarding the safety/risk profile of drugs during pregnancy is collected after the drug has been approved and used by pregnant women intentionally or unintentionally: intentionally because some conditions require treatment during pregnancy, or unintentionally because approximately half of all pregnancies in the United States are unplanned,9 so embryo/fetal exposure to medications can occur before pregnancy is detected.

Tests in animal models are a regulatory requirement for new drugs and biologics prior to approval. In some cases, these animal toxicology studies can provide a means to detect teratogenic effects. Often, however, results are not easily translated into human risk because of variations in teratogenic response among species.10 In addition, animal toxicology studies are designed so that at least one dose tested will provoke an adverse toxic response. The results at those dose levels may not predict those that might be observed at the intended therapeutic doses used in humans.11

In humans, passive data collection such as FDA's Adverse Event Reporting System (AERS) can suggest potential drug safety issues for further study. The system includes any patient population that may have been exposed to the drug. Reporting to the database is voluntary (although required for manufacturers) and underreporting is a significant issue, with extent of reporting thought to vary substantially depending on the drug, the indication for use, and the nature of the adverse event.12, 13 There is no reference group and no information is available on the number of individuals taking the drug who did not have an adverse event. It is often not clear whether the adverse event reported to AERS is a medication-related event, an event resulting from the underlying illness, or a coincidence. Since adverse pregnancy outcomes such as pregnancy losses and congenital malformations are relatively common, they will inevitably occur among exposed individuals; selected reporting of exposed cases can lead to false alarms. Consequently, although data from AERS can be useful for identifying initial signals of adverse events, it cannot be used to quantify risks for a particular product or to compare risks between drugs.14 Similarly, case series published in scientific journals cannot distinguish chance from causation or be used to quantify and assign teratogenic risks.

Information on human teratogens must come from adequately controlled epidemiological studies, which include case-control and cohort designs. Case-control studies identify births with the outcome of interest (e.g., a specific birth defect) and compare their frequency of exposures to that in a control group without this outcome. This design offers advantages in detection and confirmation of associations between prenatal exposure to the medication and the risk for rare events.15 However, case-control studies have some limitations. They collect information on exposure retrospectively, rarely have enough sample size to evaluate infrequently used medications, and can estimate the relative risks but not the absolute risks associated with the drug.

Followup studies of pregnant women have the advantage of identifying drug exposure before the adverse outcomes are recognized. In nonpregnant populations, health care utilization databases such as Medicaid claims files or records in large health maintenance organizations have become a standard source of information for drug safety studies.16 These databases are a resource for large-scale observational postmarketing studies because they offer the ability to study rare consequences of drug use. Some of these databases have limitations for the study of pregnancy outcomes because they do not routinely record evidence of pregnancy (e.g., estimated date of conception) or provide child-mother linkages. Important reproductive information, such as gestational age at birth, birth weight, and maternal reproductive history, is rarely available.17 Moreover, when exposure to the specific drug of interest involves a small fraction of the pregnant population, even these large cohorts are constrained in their statistical power. In this scenario, concentrating on women exposed to selected drugs through a pregnancy registry can increase efficiency. However, the FDA-funded Medication Exposure in Pregnancy Risk Evaluation Program has established collaboration among a selected group of large administrative databases with the ability to link mothers and babies and with linkage to birth certificates, which contain additional information.18 This resource will serve as an important tool to study outpatient dispensing of medications during pregnancy and a number of validated pregnancy outcomes.

## 3 Pregnancy Registry Objectives

The overall purpose of pregnancy exposure registries is to provide human data on the safety of biopharmaceutical products during pregnancy.1, 19 Pregnancy registries should have specific primary and secondary objectives defined a priori in a scientifically sound study protocol.2 Many exposure registries have as their primary objective to “assess the risk of major congenital malformations” in the offspring of women exposed to a given drug just before or during pregnancy. Implicit in this objective is to determine whether that risk is higher or lower than expected. Registries can evaluate multiple maternal, obstetrical, fetal, and infant outcomes, from pregnancy complications to developmental delays. Moreover, they may provide an opportunity to evaluate not only the safety, but also the effectiveness of drugs, as well as the risks associated with untreated diseases during pregnancy. They can also evaluate the effects of dose and gestational timing of exposure, as well as effect modification by maternal characteristics.1

Since the ultimate goal is to inform the decisions of medical care providers and patients, it is in the common interest of all the parties to initiate the registry as soon as possible after marketing authorization, use proactive enrollment strategies (i.e., if possible, broaden the source population to obtain, for example, 1,000 exposed women in 1 year rather than 100 per year for 10 years), and analyze the data and report findings on a regular basis.2 As more data accumulate over time, the registry can provide narrower boundaries of uncertainty around the point estimates, which leads to increasing assurance of relative safety or more precise quantification of relative risks. These issues are discussed more extensively in Sections 17 and 17.9 below, respectively.

## 4 Design

Whether stated or not, one scientific question in the evaluation of drugs during pregnancy is often “What would have been the outcome of this pregnancy had the woman not been exposed?” Since the counterfactual outcome of a given pregnancy is unknown, the closest strategy to respond to this question would be to randomize a group of women periconceptionally either to the drug of interest or to a reference group and follow them in a blinded manner until the outcome of interest is fully assessed. This design would ensure that the groups differ only in their drug exposure and that the same methodology and clinical judgment are used to assess the outcomes. The reference group could be randomized to placebo, if not treating is clinically acceptable, or to an alternative therapy, and the comparative efficacy and safety of two or more therapeutic options could be evaluated. However, since for ethical reasons pregnant women are rarely included in sufficient numbers in randomized controlled trials (RCTs) during the process of drug development, the safety and effectiveness of drugs during pregnancy needs to be studied in postmarketing nonrandomized studies.3, 19

The specific design of a pregnancy registry is determined by its purpose.1 To rule out strong teratogenic effects (e.g., more than a 20 percent risk of malformations after prenatal exposure to thalidomide), enrollment of 100 exposed pregnancies in a simple uncontrolled cohort might suffice. The effect of major teratogens is so large as to overwhelm the potential impact of common methodological biases on relative risks. However, most known teratogens are associated with a more moderate increase in the risk of relatively rare malformations.20 To detect moderate teratogens, registries need to enroll a larger number of gestations and be carefully designed.19

Although the same rigor and most principles of RCTs can be applied to any observational study, the lack of randomization calls for additional epidemiological methods.21 The following sections discuss how pregnancy registries differ from RCTs; how deviation from the standards of RCTs can compromise the validity of results; and how biases can be minimized through collection of detailed data on exposure and other maternal characteristics, close followup, accurate assessment of outcomes, and inclusion of comparable reference groups.

## 5 Study Population: Who and When

Through clear inclusion and exclusion criteria, registries target a well-defined study population that, ideally, should be closer to real clinical practice than the selected populations of a RCT. However, to the extent that pregnancy registries rely on patients' or their health care providers' hearing about the registry, contacting the registry, and agreeing to participate, there is the potential for selective enrollment. Women who do participate may differ systematically from the population of exposed pregnant women who are not part of the registry, with respect to factors related to the pregnancy outcome. Therefore, baseline risks in the registry population may differ from those in the general population of women using the drug of interest.

In assessing the relative risks associated with the drug, there is often a tradeoff between generalizability and validity. For example, generalizability would be enhanced by use of a population-based sampling strategy in situations where the underlying population can be enumerated. However, inclusion of non-motivated individuals might increase losses to followup, misclassification of information, and the variability and impact of confounders, thus reducing validity. In addition, population-based sampling strategies can be logistically complicated and would arguably estimate a similar relative risk, since a teratogenic effect found in participants would probably apply to “non-volunteers” as well.

A peculiarity of pregnancy registries is that the population can be defined based on women, pregnancies, or fetuses. A woman might have more than one pregnancy, and she might enroll in the same registry more than once. Clustered analyses are often used in this situation. In addition, multifetal gestations result in more than one fetus “enrolled” within the same pregnancy. Although there may be several ways of dealing with multiple gestations, it is prudent to collect information about all the fetuses. When reporting risks, whether using fetuses or pregnancies as the unit of analysis, both the numerator and denominator should be consistent with the choice.22

## 6 Enrollment and Followup

An ideal pregnancy cohort would enroll women at conception and follow them for months beyond delivery. However, this sequence rarely happens for logistical reasons, and consequently pregnancy cohorts have some degree of unintended truncation on both sides of the ideal followup. Left truncation occurs because followup can only start after women realize they are pregnant (in patient-initiated enrollment in registries) or health care providers identify the pregnancy in a patient (in clinician-initiated enrollment in registries), and the process of enrollment itself can further delay the inclusion. Right truncation occurs because followup would end with unknown outcomes when there are losses to followup or pregnancy terminations without fetal autopsy.

As a result, time from enrollment to end of followup can range from 1 month to over 1 year. In any study, longer followup periods naturally lead to higher opportunities for diagnosis and therefore both larger cumulative risk estimates and greater statistical power. We will examine later how inclusion of either prenatal diagnoses or outcomes identified during infancy would result in higher risks than restriction to delivery hospital discharge diagnoses. More worrisome in pregnancy registries is that selection bias can be introduced if the outcome explicitly or implicitly affects enrollment (e.g., a known outcome affects eligibility or influences self-selection) or retention in the cohort (e.g., through exclusion of study subjects after an abortion or neonatal death).

### 6.1 Enrollment

Registries should include women as soon as possible after conception, or even earlier at pregnancy planning stages, to allow the evaluation of early pregnancy events. For instance, pregnancies enrolled earlier in gestation would result in higher risk estimates for spontaneous abortions and terminations than those enrolled later. Still, unless periodic pregnancy tests are conducted, studies will never pick up fetal losses that occur before pregnancy is known.

Women should be enrolled before the pregnancy outcome is known to avoid a selection into the study affected by the outcome. Retrospective enrollment of women after prenatal screening (i.e., nuchal translucency, chorionic villous sampling, amniocentesis, alpha fetoprotein measurements, and second-trimester ultrasound— first-trimester dating ultrasounds do not assess malformations), can introduce bias towards a lower or higher risk of malformations. Bias may be introduced regardless of whether the prenatal screening test is normal or abnormal.1

Underestimation of the risk may occur if enrollment after informative screening tests are conducted selects a survivor cohort of women with uneventful pregnancies. For example, women might be less willing to contact a “pregnancy registry” after a major malformation diagnosis, clinicians enrolling patients might miss women who had a therapeutic abortion, and some registries do not allow enrollment of women with abnormal prenatal tests or pregnancy losses when an abnormality has been identified. On the other hand, overestimation of the risk might occur if participation is allowed after an abnormal test and there is a preferential enrollment of women with a diagnosis; for example, if the diagnosis prompts the exposed woman to look for information, find the registry, and enroll. These two scenarios can coexist and even occur differentially in unexposed and exposed women, leading to spurious associations. For example, unexposed women might be more willing to volunteer to be in a reference group if they are enjoying an uneventful gestation, while women with chronic conditions (e.g., rheumatoid arthritis) might contact a pregnancy registry after receiving an adverse pregnancy diagnosis, seeking both personal support and contact with peers with the same medical condition. Because this bias is difficult to identify and correct in the analytic phase, it needs to be prevented in the design by enrolling subjects prospectively before the outcome is known.

### 6.2 Followup

Another peculiarity of pregnancy studies is that followup needs to go beyond the onset of the outcome under study. For most major structural congenital anomalies, the theoretical followup would be from conception to the end of fetal organogenesis (i.e., on average 3 gestational months). However, one often learns about the fetal outcomes only after birth. Longer followups will identify more congenital problems, since some structural and many functional malformations might become clinically apparent only months or years later.19, 23 In pregnancy registries, followup typically stops at 3 to 12 months after the end of pregnancy. Some registries restrict the cohort to infants with a minimal standard followup time, such as at least 3 months after birth. (Of note, fetal deaths and infant deaths before the minimal followup should also be included in the assessment to avoid excluding lethal malformations). Efforts should be made to minimize losses to followup and to obtain outcome information for all participants. Information needs to be collected on the number of losses and, if possible, on their reasons, in order to assess whether they are similarly distributed among the exposed and unexposed populations.

## 7 Exposure Ascertainment

How registries collect information can affect the accuracy of the data. Some registries obtain information from the women themselves. Women generally know more about their habits, occupations, medical and obstetrical history, and compliance with the drug than individual health care providers. Other registries rely on reporting by the clinicians and have no contact with the patients. Clinicians can provide more complete and accurate information regarding diagnoses and indications.24 However, there is a risk of exposure misclassification if women stop or incompletely comply with the prescription drug regimen during pregnancy. A woman might be more willing to tell an interviewer not related to her care than to tell her doctor that she decided to reduce her dose or quit taking a medication. Including unexposed subjects in the exposed group (i.e., false positives) can dilute any potential association.

In order to maximize the quality of data, the combination of several sources of information is an optimal strategy. With adequate help, women can recall exposure during pregnancy. As noted previously, they should be enrolled before the pregnancy outcome is known to reduce selection bias, as well as to obtain reliable prospective information on exposure and other characteristics not affected by the outcome. One interview should take place at enrollment (i.e., during the first trimester), and at least one interview should take place postpartum (e.g., 2 months after end of pregnancy). Additional interviews (e.g., midpregnancy in order to update exposure information; 12 months after delivery in order to evaluate development) might be useful depending on the objectives of the pregnancy registry. Data from treating physicians can document the medical condition and confirm the prescription. Confirmation of exposure should be blinded to the outcome.

## 8 Exposure Definition

If one is concerned about structural malformations, the etiologically relevant period of exposure is the first trimester of pregnancy. To identify this period, one needs to establish gestational timing. Obstetricians typically time pregnancies from the first day of the last menstrual period (LMP), determined by maternal recall or, preferentially, by a more accurate early pregnancy ultrasound. Depending on the pharmacological characteristics of the drug, the specific defect, and the accuracy of timing information, the window of interest might be the second and/or third month, any time during the first 4 months after the LMP, or even weeks before LMP for drugs with long half-lives or unspecified period of effect (e.g., vaccines). Exposures later in pregnancy can adversely affect other outcomes.25-27

Treatment strategies change during pregnancy, and doses are commonly adjusted. Therefore, it is recommended that detailed information be collected on start and stop dates, dose, frequency, duration, and indication.28 Some medications (e.g., anticonvulsants) are prescribed in combination with other drugs. The effect of polytherapy resulting from concomitant treatments, or from switching drugs, within the first trimester should be explored in the analyses. Not only the number of drugs, but which drugs are combined, might affect the outcome of interest. Although the power is usually limited, analyses of dose response can inform recommendations, analyses of specific timing within the first trimester can assess biological plausibility, and analyses of indications might help explore confounding. If possible, maternal body mass index should be considered when evaluating dose effects.

## 9 Covariates: What Else To Collect?

There is always a tension between simplicity and a desire to be comprehensive. Although there is no general rule, one widely accepted principle is that quality is more important than quantity—if the information is not trustworthy, do not collect it. Minimizing the effort and time from participants can increase both the willingness and the quality of participation. Necessary information on exposure, outcome, and key confounders (e.g., history, status, severity, and management of the indication) should take preference over desirable but less useful information. Most registries collect information on demographics, concomitant illnesses and medications, and reproductive history. A list of variables commonly collected in pregnancy studies is provided in Table 21–1.

Table 21–1 Variables commonly collected in exposure pregnancy registries

Identification | Exposure | Outcome | Covariates
Study ID Date of enrollment LMP date or EDD Gestational age at enrollment Date of first data collection Date(s) of followup data collection(s) Date of end of followup Followup status (e.g., complete, loss to followup, withdrawal) Contact information: Woman Alternative contact(s) Obstetrician/prenatal health care provider: Specialist Pediatrician | Drug For each drug, each episode of use, and each dose if changed: Start date Stop date Indication and measure of disease severity (e.g., CD4 count for HIV patients, type of epilepsy and convulsions during pregnancy for anticonvulsants) Dose Route Frequency Duration | Sex Status: Live birth Elective termination Spontaneous abortion Late fetal death Number of fetuses (singleton or multiples) For fetal loss: Date end of pregnancy Reason for termination For live birth: Date of birth Birth weight Birth length Head circumference Gestational age at birth Conditions at birth (e.g. admission to intensive care unit, drug withdrawal syndrome) Congenital anomalies: Specific defects Date of diagnosis Methods of diagnosis Date and results of any prenatal testing Obstetric outcomes: Delivery (vaginal, C-section type) Preeclampsia Premature labor Preterm delivery Gestational diabetes | Demographics: Maternal age Race Occupation Education level Pre-pregnancy weight and height Reproductive history: Number of previous completed pregnancies and miscarriages Fertility interventions for past and current pregnancy Family history of defects (specific defect and degree of relationship) Habits: Cigarette smoking Alcohol intake Use of illicit drugs Chronic medical conditions: Diabetes Pregravid obesity Hypertension Epilepsy Depression Other psychiatric disorders Hepatitis Thyroid disease Autoimmune disease Asthma Sexually transmitted disorders AIDS Concomitant medications, including folic acid supplementation and potential teratogens.

## 10 Outcome Ascertainment

The source of information for outcomes in pregnancy registries is critical. Although registry designs that incorporate interviews with pregnant women can provide an initial source of data regarding the results of prenatal diagnosis, postnatal events, and malformations that are recognized during longer term followup periods, in most registries, validation by the health care provider of any maternally reported diagnosis is an important criterion for inclusion of specific outcomes such as major congenital anomalies (see Outcomes Definitions below). In registries in which the outcome is routinely collected from the woman and validated by health care providers, the mother's report can correct potential false negative reports from one clinician; in comparison, registries in which the outcomes are reported only by the provider rarely include maternal validation. In some circumstances, a more stringent level of validation might be required to confirm an outcome (e.g., an echocardiogram to validate the presence of specific heart defects). Requiring commitment from registrants at enrollment to provide consent and medical release of information from obstetrician and specialists can select a motivated patient population and minimize loss to followup and maximize access to medical data.2

Whether the exposure is ascertained from the patient or from the clinician, it is important to obtain delivery data from the obstetrician or hospitalization records to ascertain the outcome accurately. It is also important to follow up with subsequent providers, such as the infant's pediatrician and other specialists, because those treating a woman for a non–pregnancy-related condition often know little about obstetric or pediatric outcomes (e.g., a woman's neurologist might not know about the patient's preeclampsia), and obstetricians often know little about the infant after delivery.1, 19 Obtaining this information may require the woman's consent and therefore contact with her. In addition, treating physicians might have a legal or ethical conflict of interest if they are asked to report on a pregnancy outcome when they were responsible for the exposure.

It is important to recognize that maternal report alone can result in misclassification of the presence or absence of any defect and/or the presence or absence of a specific defect. Although specificity is most relevant for the evaluation of infrequent outcomes, to maximize sensitivity medical validation may be required for all births and not just those in which the mother reports an abnormality.

Other primary or supplemental methods of ascertainment of birth defect outcomes can be employed. These include linkage to claims data, public birth registries, or birth defects surveillance systems. In any case, comparable methods for ascertainment of outcomes must be used in the exposed and reference groups.

## 11 Outcome(s) Definition

As part of the study design, pregnancy registries must set a priori criteria for defining outcomes. Outcomes are typically ranked in order of importance to the registry's objectives. For example, most pregnancy registries identify major structural birth defects as the “primary” outcome of interest. This outcome is frequently defined as primary because identification of an increase in major malformations, particularly specific major malformations, in association with a given gestational exposure may indicate a teratogenic effect. In addition, some pregnancy registries incorporate a measure of “minor” structural defects as an outcome representing a broader spectrum of potential structural differences that may be attributable to an exposure.

Other “secondary” endpoints frequently include measures of fetal growth deficiency, preterm delivery, spontaneous abortion or stillbirth, and elective terminations. Some pregnancy registries incorporate longer term measures of outcomes that can include, for example, postnatal growth deficiency, cognitive and behavioral development, or measures of immune function, depending on the characteristics of the exposure under study in the registry. However, the cost and logistics of following children over time usually are prohibitive.

Using the primary outcome of major structural defects as an example, but relevant to all outcomes in any pregnancy registry, the following definitions must be determined a priori.

### 11.1 Inclusion/Exclusion Criteria for a Defect To Be Defined as “Major”

Criteria for defining defects as “major” must be established for a pregnancy registry. For example, major structural defects might be defined as abnormalities in structural development that are medically or cosmetically significant, are present at birth, and persist in postnatal life unless or until repaired. Similarly, criteria must be established for defects that will be excluded. For example, those that are transient and maturational and do not represent an abnormality in embryonic or fetal development, such as a patent ductus arteriosus or an inguinal hernia that might occur in a preterm infant simply as an artifact of shortened gestational age, might be excluded. Another example of an excluded defect might be a small muscular ventricular septal defect that may spontaneously close with no consequences for the infant. Attention must be paid to the comparability of definitions for inclusion and exclusion between the exposed and the reference groups.

Frequently, pregnancy registries employ an existing standard coding system for inclusion and exclusion of structural defects, such as that developed by the U.S. Centers for Disease Control and Prevention's (CDC) Metropolitan Atlanta Congenital Defects program.29 This system was created and is maintained for use in an ongoing population-based surveillance program for birth defects that are identifiable up to 1 year of age. For some pregnancy registries, additional definitions or modified inclusionary/exclusionary criteria may need to be employed, depending on the length of followup or the specific outcomes of interest. Even with standard coding criteria, the information available for some reported defects may be insufficient or ambiguous for classification, such that an additional level of review is required to classify the defect appropriately. A method for expert adjudication of defect classification, blinded to exposure status, is an important component of a pregnancy registry.

Minor malformations are defined as those uncommon structural differences in the infant that have no serious medical or cosmetic consequences (e.g., an extra hair whorl on the head). Although these minor structural defects are of potential interest as more subtle measures of outcome, they may not be reliably assessed and therefore are frequently excluded unless they are uniformly evaluated in all patients. Similarly, positional deformities are often excluded (e.g., abnormal head shape or plagiocephaly that spontaneously resolves shortly after birth).

The source of information regarding a major structural defect must also be defined as meeting the criteria for inclusion. For example, maternal report of a malformation with no validation by a physician or postnatal diagnostic test may be defined as insufficient for inclusion of a major defect. Another example of a situation that might be defined as exclusionary is a defect that is suggested through prenatal diagnostic tests but for which no postnatal validation is available.

### 11.2 Timeframe of Diagnosis

A specified period for followup, during which standardized efforts will be made to collect outcome information on major birth defects, should be determined as part of the pregnancy registry design. As length of followup increases, the baseline risk of major structural defects is expected to increase because not all structural defects are reliably recognized at birth. Ideally, the longer the followup, the more complete an assessment of major birth defects could be. Specific outcomes of interest for the exposure under study may require longer followup to be appropriately assessed. However, the length of followup selected for the registry may be influenced by the availability of resources and the registry's ability to maintain contact with registry participants and/or health care providers over a longer term. For comparability reasons, it is essential that the timeframe for diagnosis be identical in the exposed and the reference population or group.

In addition, the case of major birth defects occurring in pregnancies that end in embryonic or fetal demise must be considered in the registry design. Major defects might be identified in spontaneous pregnancy losses by postnatal pathology, and criteria for inclusion of those defects must be established, as not all spontaneously aborted pregnancies or stillbirths will be uniformly evaluated for the presence or absence of defects. In the special case of elective terminations, criteria for ascertainment of malformations are critical because terminations for defects that are identified on prenatal diagnosis may represent an important subset of outcomes within the registry. Elective terminations for social reasons may not be uniformly evaluated by prenatal diagnosis for major structural defects. For these reasons, many pregnancy registries treat malformations identified in pregnancies ending in live birth separately from malformations included in the overall sample of registry pregnancies including terminations, spontaneous abortions, and stillbirths. Failure to include defects detected among terminations can decrease power and introduce bias, particularly for defects for which termination is often chosen after prenatal diagnosis (e.g., neural tube defects).

### 11.3 Analytical Approach

No known teratogen increases the risk of all major birth defects. Typically, a specific defect or pattern of defects occurs with increasing frequency following a teratogenic exposure in the critical gestational window for susceptibility. However, specific major defects are rare events in the general population—the most common occur no more frequently than approximately 1 in 1,000 live births. Pregnancy registries usually do not have sufficient sample size/power to evaluate increased risks for specific defects unless the relative risks are quite large. Therefore, most registries compare the overall proportion of all major defects combined in the exposed group to the overall proportion in the reference group. The rationale for this approach is that if specific defects are increased following exposure, these specific defects will incrementally inflate the overall proportion of malformations in the exposed sample and therefore reflect the excess risk associated with that exposure. For example, if the baseline risk of major malformations is 3 percent and the risk of neural tube defects is 0.1 percent, a fivefold increased risk of neural tube defects would inflate the overall risk to about 3.4 percent. Although the analytic approach for a registry may be based on a comparison of all malformations combined, it is important for pregnancy registries to evaluate any potential excess of specific defects in the exposed group, even if this evaluation is descriptive.

In some registry designs, it is argued that malformations of known etiology should be excluded from the overall proportion of major structural defects, as they do not have the potential to have been “caused” by the exposure. Examples might be chromosomal anomalies, those defects that have a known single gene cause, or defects that occur in families with a positive history for that defect. The rationale for these exclusions is that inclusion of defects not thought to be caused by teratogens can decrease power to detect an overall difference in risk between exposed and unexposed fetuses. Arguments against exclusion of such defects in the analysis are that the true cause of the defect may not be known and that it is possible that exposure to a medication modifies other risks for that defect in a multifactorial manner. Therefore, by excluding such defects one could miss the effect.30 Inclusion or exclusion of chromosomal defects or those of other known etiology may also be driven by the inclusion or exclusion of those defects in the reference population that is selected for comparison.

## 12 Reference Group(s): Internal or External, Exposed or Unexposed?

A critical element for pregnancy exposure registries is the choice of comparator groups. The most valid reference group will have comparable (1) outcome definition (e.g., exclusion of minor anomalies); (2) outcome assessment (e.g., intensity of screening, frequency of terminations, inclusion of prenatal diagnoses, availability of diagnostic tests, start and stop of followup);23 (3) selection of subjects into the study (e.g., gestational age at enrollment); and (4) baseline risk (e.g., distribution of risk factors, including indication). Ideally, each registry is constructed to include one or more internal reference groups. When this is not possible, an external reference group must be selected with care. Each comparison group has its advantages and disadvantages. For example, an external population-based reference group is generally larger and can provide more stable estimates for specific malformations, while an internal comparison group, which may be too small to support assessment of specific malformations, may be able to provide more comparable estimates for malformations overall. More than one comparison group can be used to increase the study generalizability. In anticipation of potential conflicting results, however, a primary comparison group or groups should be identified and justified a priori.

External comparators are usually considered less valid than internal comparators; for example, an RCT or observational study on the relative risk of stroke in an elderly population exposed to a drug would never use an external reference. However, pregnancy registries often compare their estimates with the background risk in “standard populations” such as the CDC's Metropolitan Atlanta Congenital Defects Program, where the frequency of malformations among pregnancies of 20 weeks or greater is 2.1 percent when diagnosed prenatally or within the first week of life, and 2.6 percent if infants are followed until the first birthday;19, 23 or European Congenital Anomalies and Twins Registers (EUROCAT) data in Europe, where the prevalence of malformations at birth is 2.0 percent.31 Two advantages of the use of available data from large external reference populations are that it avoids the costs in time and money of enrolling unexposed subjects, and that it provides stable risk estimates for common specific malformations in the general population.

External reference groups must be used with caution, since the estimated risk of “major malformations” can vary widely depending on the population, the definition, and the ascertainment methodology. When external references are the only alternative, they must be appropriate to the population being studied. Analyses should at least take into account the characteristics of the surveillance program and use the same methodology in their exposed group. For example, characteristics to be considered are whether prenatal diagnoses and terminations were counted, whether malformations were identified during the delivery hospitalization or also through followup over a number of months, and whether chromosomal malformations and minor malformations were included. Many registries use external references as a necessity. Information from these sources can be helpful, particularly when there are no other data available, as long as findings are interpreted with caution. For example, external references can identify major teratogens (like thalidomide), generate hypotheses when unusual patterns of malformations are identified, and inform the need for additional, targeted, epidemiological studies.24

Some registries enroll an internal reference group of unexposed women who undergo the same processes as the exposed; these registries subsequently adjust for potential confounding by matching or adjusting for key covariates. There is still some risk of differential gestational time at enrollment (exposed women may tend to enroll earlier) and lack of comparability (unexposed women rarely have the underlying condition for which the drug was indicated). To make groups more comparable, some registries use women exposed to other non-teratogenic drugs as the reference (e.g., OTIS registries)32 or enroll pregnant women with a common condition or indication treated with various drugs or untreated (e.g., the multi-sponsor North American Antiepileptic Drug [NAAED] Pregnancy Registry,33 and the HIV Antiretroviral Pregnancy Registry34). More recently, the scientific community has moved toward the evaluation of the comparative safety and efficacy of different treatments for similar indications, in similar populations whenever possible. This approach enhances the comparability of groups, although sometimes more severe conditions are channeled to specific treatment while milder ones can remain untreated; thus, confounding by severity or type of disease is still possible. In addition to improving validity, using alternative treatments as a reference would answer the clinically relevant question of “how to treat” rather than whether to treat. Moreover, safety data is often needed for multiple drugs with the same indication, evaluation of a variety of drugs used to treat the same condition could be most efficient. The feasibility of multiple-drug registries depends in part on the sponsorship.

Taking advantage of the etiologically relevant periods of exposure during pregnancy, some studies compare first-trimester use of the drug with second- or third-trimester use. These comparisons are only possible for nonchronic treatments, and researchers should consider that the outcome can affect the opportunity for exposure after the first trimester. For example, if the pregnancy is terminated because of a malformation, there would not be second- or third-trimester exposures; therefore, later exposures might be artificially associated with lower risks.

## 13 Analysis of Registry Data

Pregnancy registries frequently include multiple outcomes as endpoints and may have more than one comparison group; in addition, as stated above, major birth defects among live births may be evaluated separately from major birth defects among all pregnancies. To address the problem of multiple comparisons in analysis and interpretation of registry data, it is essential to establish an analysis plan that identifies the primary hypothesis being tested—typically the proportion of pregnancies involving a major birth defect—and to specify which are the primary groups being compared.

Similarly, the analysis plan should attend to the design of the registry and the expected sample size. For example, registries that involve multiple centers/multiple countries should use appropriate conditional methods of analysis that account for center. For outcomes with low frequencies (e.g., major structural defects), sample size projections should indicate when exact methods must be used for analysis. To evaluate the robustness of findings in the registry, the analysis plan can incorporate a plan for post hoc sensitivity analyses under various scenarios.

## 14 Statistical Power, Registry Size, and Duration

The projected sample size for a specific pregnancy registry is affected by the frequency with which the medication is used by women of reproductive age, the proportion of exposed pregnancies it is estimated are possible to identify and recruit into the registry, and the scope of the registry (local, national, international). The power of the study to detect an effect at or above a certain level is affected by the sample size and the baseline risk for the outcome in the population.19 The estimated losses to followup will affect the useful sample size. The duration of followup for outcome assessment will affect the cumulative risk estimate. Missing therapeutic abortions will affect both.

If the medication under study typically is taken only for a few days or intermittently, this fact should be considered in calculations of power and sample size. The effective sample size of pregnancies exposed only in specific gestational windows of time (any one of which may be a risk period while others are not) may be much smaller than the registry's overall projected sample size of pregnancies exposed. These factors must be balanced against the amount of time needed to accumulate a sample size that is sufficient to produce a clinically relevant result.

For example, in a pregnancy registry that compares the overall proportion of pregnancies resulting in an infant with a major birth defect among exposed women with the proportion in an external reference population with a baseline prevalence of major defects of 3 percent, a sample size of 200 exposed live born infants would be sufficient to detect a 2.2-fold relative risk with 80 percent power at an alpha of 0.05. However, the same sample size of exposed live births would be sufficient to detect only a 10.4 or greater relative risk for cleft lip with or without cleft palate.34

Because of the limits of power associated with typical sample sizes for pregnancy registries, especially in detecting risks for specific birth defects, an approach that has been used in some registries is the “rule of three”: An alert is triggered when three or more occurrences of specific defects are reported for a specific exposure. This rule is based on the less than 5 percent likelihood of a chance finding of three or more occurrences of the same specific, relatively rare, defect in a cohort of 600 or fewer subjects. Although some defects or defect groups occur frequently enough that the “rule of three” would not apply, this method can be used to flag an unusual finding for further review.34

## 15 Biases

### 15.1 Selection Biases

Because pregnancy registries typically enroll women only after recognition of pregnancy and in some cases much later in pregnancy, the group of enrollees is a selective group of pregnancies that have survived to that point in gestation and may have a shortened remaining period at risk of incurring the outcome of interest. There is “left truncation” of the registry cohort such that it is devoid of women who have already had a spontaneous abortion, an elective termination, or a stillbirth, depending on the gestational age of enrollment. Although statistical methods can be used to address left-truncation, survivor bias threatens ability to evaluate risk for pregnancy outcomes including birth defects, and calls for a registry design that encourages recruitment of participants as early in gestation as possible. In the extreme, one cannot study infertility in a cohort of pregnancies because, by definition, the women have conceived. Nor would one estimate the incidence of spontaneous abortions in women enrolled after 20 weeks of pregnancy. Spontaneous abortions can still be evaluated when women are enrolled during the first trimester, by assessing the rate of miscarriages per gestational month, thus taking into account both the decreasing trend as gestation progresses and the gestational time at enrollment.

Early enrollment is also of benefit with respect to biases potentially introduced by prenatal diagnosis. Prospective registry enrollment before any prenatal diagnostic test for major birth defect avoids bias in the direction of an increased risk for defects so identified, or in the other direction if women enroll preferentially after prenatal diagnosis that has shown no defect. Pregnancy registry guidelines recommend that only participants enrolled prior to prenatal screening be included.2 However, as prenatal diagnosis becomes feasible earlier in gestation, this becomes more difficult to achieve.

Many registries also collect data retrospectively, but these data should be analyzed separately. Women enrolled after an abnormal pregnancy test can be analyzed as case series in passive surveillance systems of spontaneous adverse event reports.2 Malformations can be evaluated for biological plausibility, and specific patterns of malformations or distinct congenital abnormalities can generate hypotheses. On the other hand, retrospectively enrolled subjects without malformations would offer limited information, therefore, the benefit (and ethics) of including these women is questionable.

Registries should report the gestational age at enrollment for their exposed and reference groups. If enrollment time differs, methods should be applied that adjust for left censoring, such as restriction to prospective pretests enrollees.

Another bias might be associated with right truncation of the registry cohort. This occurs when pregnancies with unknown outcomes are considered ineligible for analyses. By excluding terminations, spontaneous abortions, and losses to followup, one assumes that the exposure had the same effect in these pregnancies as in those that remain under observation. Such an assumption is less plausible if the exposed group has a higher frequency of these outcomes than the reference group. The frequency of spontaneous and therapeutic abortions, losses to followup, and withdrawals should be reported for the exposed and reference groups. Of note, a higher frequency of terminations among exposed women might reflect a higher risk of malformations, as well as more fear of malformations with consequent abortion if the drug is suspected of being teratogenic.

Bias may also occur with events that shorten the followup (e.g., preterm delivery that cuts the possible number of weeks of exposure to the drug of interest). The assessment of transient exposures (e.g., vaccines) during pregnancy in relation to outcomes associated with shorter gestations (e.g., preeclampsia, prematurity, pregnancy weight gain) needs to take into account the smaller opportunity for exposure in shorter pregnancies.

Biases can also be introduced into the analysis by stratification or adjustment for covariates that are themselves affected by the exposure of interest and that are affected by the outcome or share common causes with the outcome (e.g., adjusting for gestational age at birth when studying the effect of a pharmaceutical on structural malformations).35-37

### 15.2 Information Bias

As noted above, pregnancy registries are preferentially “prospective” in design. With prospective design, the outcome cannot directly affect the accuracy of exposure information, and any misclassification of drug exposure tends to be nondifferential with respect to the outcome. However, nondifferential misclassification of exposure is still problematic for safety evaluation, since it tends to bias any potential effect toward the null. It is therefore crucial to maximize the quality of drug exposure information.

When the women provide information on exposure, the accuracy of the recall can be maximized by using structured questionnaires, detailed questions, and calendars to help establish gestational timing and enhance recall of dates. Maternal reports on drug utilization are sometimes cross-validated with medical records. When the health care provider is the only source of data, information on prescriptions may not reflect the real use of the drug during pregnancy if patient compliance is incomplete. Since pregnancy registries typically focus on uncommonly used medications, the impact of false positives among the exposed group is much greater than the occasional inclusion of false negatives among the unexposed reference group.

At the time of enrollment in the registry, women are reporting their medical history retrospectively, knowing that they are enrolled in the registry because there is lack of information on the safety of the drug under study. This situation can potentially influence the accuracy of recall for baseline covariates (i.e., recall may be more accurate for exposed than for unexposed groups because there is a different motivation to recall a medical history) and affect the ability to control for confounding. For this reason, methods for validation of key covariates are of benefit.

Diagnostic bias, or outcome misclassification, also can occur in pregnancy registries. These biases can be either nondifferential or differential between the exposed and the reference group, and can bias the estimate of an effect toward or away from the null. For example, participation in the registry itself or concern that a drug exposure might pose a risk could lead to more access to or uptake of prenatal diagnostic measures such as ultrasound and to more careful examination of infants for defects postnatally, potentially leading to differential accuracy in detection and classification of defects among exposed and unexposed groups. The risk of differential outcome classification among the exposed and the reference group is greatest when external control reference groups are used.

As mentioned above, reported major malformations must be validated. Although neither treating physicians nor women are blinded to the treatment, registries can do blinded validation and adjudication of outcomes. To detect malformations not reported by the patients, records for all pregnancies would have to be reviewed. For example, women might be less likely to volunteer information regarding male genital malformations in their infants, which could result in under-ascertainment of these malformations. To detect malformations identified by screening and frequently terminated (e.g., anencephaly), therapeutic abortions need to be included. To detect an increase in abnormalities incompatible with life, it is important to collect information on autopsy results at stillbirth and, if possible, on examinations of the fetus after spontaneous or induced abortion. The study of spontaneous abortions and pregnancy terminations itself presents an additional methodological challenge, especially in countries where abortions are illegal or when studies include pediatric populations, because induced fetal losses are sometimes categorized as spontaneous in medical records, and questions about terminations might be considered sensitive.

### 15.3 Confounding

Several sources of confounding may affect pregnancy registries, as in any other observational study. Socioeconomic status, maternal age, tobacco and alcohol use, illegal drug use, maternal body mass index, and vitamin use are examples of potential confounders that might be related to, or impact, the exposure under study and are also risk factors for some pregnancy outcomes.

With medications, there is the concern of confounding by indication (e.g., the association of a weight loss drug with birth defects might be confounded by the maternal obesity the drug is used to treat). Confounding by indication is difficult to address in nonrandomized studies for common chronic conditions such as depression, asthma, epilepsy, HIV, and autoimmune diseases, where separating the effect, if any, of the drug from the underlying disease can be challenging. A related form of confounding that may be of concern is channeling bias (i.e., women with more severe underlying disease may be most likely to be selected to receive the drug of interest).

Each of these potential confounding concerns provides a strong rationale for inclusion of actively recruited comparison groups that are matched to the exposed registry participants on the maternal underlying disease and, to the extent possible, similar in distribution of maternal disease severity.

## 16 External Validity or Generalizability

As mentioned above, pregnancy registries typically rely on volunteers to participate. With appropriate selection of comparison groups and control for sources of confounding, pregnancy registries can make assertions about internal validity. However, there is usually little known about the characteristics of the entire population of exposed pregnant women from whom the sample is drawn. For this reason, it is difficult to make conclusions about external validity or generalizability for any pregnancy registry. If the participants represent a select group, it may be difficult to generalize the findings from the registry. However, the registry volunteers would have to differ from nonparticipants with respect to some characteristic that modifies the effect of the drug on the pregnancy outcome (e.g., a teratogenic effect might vary by race or by baseline folate levels in the population).

## 17 Operations

### 17.1 Study Protocol

Pregnancy registries are scientifically rigorous studies designed to monitor safety of product use in pregnancy. As such, they have formal written protocols based on epidemiologic principles and on regulatory authority guidance documents for pregnancy registries.2, 5 A pregnancy registry protocol should include a brief and cogent review of the literature, registry objectives, study design, detailed data collection procedures including sources of data, inclusion and exclusion criteria for patient enrollment, operational aspects of enrollment and retention, definitions of relevant endpoints, analytic considerations, statistical plan, regulatory and ethical considerations, reporting and publication plans, governance, and criteria for registry termination. While RCT protocols are registered (e.g., on ClinicalTrials.gov), it is still controversial whether those for observational studies should also be registered.38

Pregnancy registries have procedural differences distinct from RCTs and from other observational study designs. Thus, they often require specific standard operating procedures that clearly document their unique processes. Each pregnancy registry should also have its own registry management plan that serves as the registry team's roadmap. For more details see Chapter 2, Section 2.10.

### 17.2 Human Subjects, Informed Consent, and Medical Records Release Forms

Pregnancy registries involve human subjects research and thus institutional review board approval; informed consent of participants; and protection of confidentiality in data collection, data storage, and publication. Pregnant women are considered a “vulnerable” population in legal/ethical terms, but, importantly, unlike other populations considered in this section of regulations (mentally challenged patients, inmates in penal institutions, and children), they are able to give consent. Therefore, registries must adhere to guidelines for human research protection in pregnant women. Pregnancy registries are typically considered minimal risk protocols. As with participation in any research of this type, there is the potential for loss of the confidentiality of the information provided. Methods to manage this risk must be in place and communicated to the potential participant. There is also the psychological risk of participation in a pregnancy registry that may occur when a woman becomes more aware of the potential effects of exposure on the fetus. Resources for expert counseling on fetal risks are available in the United States and Canada through the Organization of Teratology Information Specialists ( https://www.mothertobaby.org/).

Informed consent is typically required for participation in a pregnancy registry. Some registries collect data directly from health care providers without collecting patient identifiers. These types of registries may qualify for a waiver of informed consent. For pregnancy registries in which the patient is identified and data are collected from multiple sources, informed consent is required. However, under several conditions, signed informed consent may be waived and verbal consent allowed. Additionally, in order for pregnancy registries to collect data from a woman's health care provider(s) and/or her newborn's pediatric health care provider, the woman must complete medical release forms for each clinician who will report data or provide medical records to the registry. Chapter 7 thoroughly discusses the application of ethical principles for registries.

### 17.3 Recruitment and Enrollment

In some registries, pregnant women self-identify and self-enroll by calling a toll-free number that can be found in key Web sites, printed materials in specialists' offices, or drug inserts. In other registries, women are referred by general practitioners, specialists treating the condition of interest, or obstetricians. Direct enrollment of women may allow inclusion of participants earlier in gestation, since they are usually the first to know about their pregnancy. Enrolling women directly may also facilitate pregnancy and postnatal followup. However, for some drugs, it might be unrealistic to expect self-enrollment and, for some conditions, it might be more efficient to identify eligible women through specialists. Some countries do not allow self-enrollment. Who initiates enrollment has implications for data collection and informed consent processes.

Pregnancy registries can be conducted by regulatory or other government agencies, academic centers, contract research organizations (CROs), or drug manufacturers. Who sponsors and who conducts the registry can affect the participation of health care centers, some of which may have barriers for collaborations with industry. Biopharmaceutical companies sometimes identify exposed pregnancies as outcomes reported to their surveillance system for drugs not recommended for pregnant women. If identified and enrolled before prenatal tests, these pregnancies can be followed, yielding a pregnancy registry nested in a passive surveillance system.

To maximize enrollment and maintain efficiency, pregnancy registries typically do not use a traditional “site-based” approach. Rather they employ a single coordinating center that recruits and enrolls all eligible pregnant women as soon as possible after conception. The number of coordinating centers that would make the study feasible varies among countries and among registries. Therefore, awareness campaigns must reach out to pregnant women and their health care providers in a broad variety of settings. A carefully constructed awareness plan should be designed specifically for each pregnancy registry, accounting for the aims of the registry, its target population, and its geographic scope. In general, the plan should incorporate a variety of persistent awareness strategies to ensure broad coverage, including announcements of the registry with contact information posted in the following:

- Product label
- Registry and/or product Internet sites
- Personal mailings to health care specialists, particularly high prescribers and high-risk obstetricians
- Professional journals
- Exhibits or scientific presentations at professional meetings
- Lay magazines
- Advocacy group newsletters and/or Internet sites
- Social media

For pregnancy registries sponsored by individual biopharmaceutical companies, promotional materials are subject to 21 CFR 314.81(b)(3) or 601.12(f)(4), and should be submitted to the FDA Division of Drug Marketing, Advertising, and Communications. In general, registry recruitment and awareness materials should not promote use of the product in pregnancy nor imply that the product is safe and effective in pregnancy unless sufficient scientific evidence exists to support these claims.

Enrollment may also be affected by the lag time between approval of the pharmaceutical and launching of the registry. Awareness and interest may peak right after approval, which is also the ideal time to collect safety data in the postmarketing setting. Streamlined procedures for informed consent and data privacy/HIPAA authorization have been demonstrated to increase enrollment in pregnancy registries.39

### 17.4 Retention of Participants During Followup

Participant retention is crucial to achieving the registry goals. Retention can be encouraged by engaging registry participants, including pregnant women and their health care providers, in the reporting process, and making it as easy as possible to report data to the registry. Registry staff should be trained to collect data for observational studies from both patients and health care providers who do not usually participate in research activities. They should develop a rapport with the reporters that facilitates data collection and promotes retention through relationship building.

Streamlined data collection processes and simple, concise data collection forms are essential for reducing the burden of reporting. For registries sponsored by pharmaceutical companies, duplication of work because of safety reporting should be avoided as much as possible. A small monetary stipend may also encourage retention but may not be universally accepted by registry reporters. For health care providers, especially obstetric care providers, registry data are often more valuable than a stipend. Giving interim data reports to health care providers who report data to the registry is a powerful recruitment and retention incentive.

### 17.5 Data Collection

Like any other epidemiological study, registries can benefit from the technologic advances in communications (e.g., ability to enroll subjects through social networks and collect data through confidential Web sites). Most registries enter the data directly into an electronic database, either from records or questionnaires or by means of computer-assisted telephone interviews. To ensure confidentiality, identifiers should not be included in the database containing clinical information. The goal is to make reporting data to the pregnancy registry as easy and unobtrusive as possible. Providing a variety of data-reporting mechanisms that are simple to use and fit the reporters' preferred communication practices facilitates recruitment and retention. If feasible, a pregnancy registry should be designed to allow participants to report data through telephone interviews; paper data collection forms that can be mailed, scanned, or faxed to the registry; simple Internet-based electronic data capture systems; and mobile applications. For details on these data capture systems, see Chapter 11, Section 2.3.

Pregnant women are ideally enrolled into a pregnancy registry before or soon after the exposure of interest and then followed throughout pregnancy. If a live infant is born, the infant may be followed for a period typically ranging from 3 to 12 months. Data may be collected at several different time points:

- At enrollment, information may be collected on product exposure(s), maternal characteristics, prenatal testing, and other baseline data.
- During the second and/or third trimester of pregnancy, a brief update on the status of the pregnancy and exposures may be obtained.
- At the end of pregnancy, information may be collected on additional exposures during pregnancy, risk factors, and details regarding the pregnancy outcome, including any congenital anomalies, gestational age and birth weight, and perinatal complications.
- For live births, data may be collected at several points in time (typically 3, 6, and/or 12 months) on infant characteristics and health outcomes including congenital anomalies, functional or developmental deficits, and other outcomes pertinent for the drug of interest.
- Targeted followup may be needed to collect additional detailed data on specific outcomes of interest.

The source of baseline and followup data is an important consideration. It is best to evaluate all options for obtaining data to determine the most appropriate source for the specific data requested. The pregnant woman can provide detailed data on drug use including exposures to the drug of interest as well as other drugs, on relevant risk factors, and on the pregnancy outcome. Her health care providers, such as the prescriber, specialists, and/or obstetrician, should be able to provide or verify this information. The collection of data from a variety of sources throughout pregnancy and during infancy contributes to the accuracy and comprehensiveness of pregnancy registry data. Requiring information from multiple health care providers, as well as from the patient, is a distinct challenge of pregnancy registries.

Data quality is of the utmost importance in a pregnancy registry, and multiple levels of quality assurance should be employed, beginning with the design of data collection instruments. Instruments should be designed with care, thoroughly vetted, and pilot tested to ensure ease of reporting valid, reliable data. Instructions for self-reporting should be clear and succinct. Electronic data capture systems should include validity checks. If interviews are to be used, the interviewers should be thoroughly trained to conduct neutral, unbiased interviews using detailed interview scripts. Once captured, the data should go through a rigorous cleaning and quality assurance process to reduce errors, missing data, and misclassifications. When possible, patient-reported data should be verified by health care providers or medical records.

### 17.6 Adjudication of Outcomes

Many pregnancy registries enlist the services of a clinical geneticist or dysmorphologist to review and classify all congenital anomalies. A standardized classification system should be used, such as the CDC's Metropolitan Atlanta Congenital Defects program.29 The assessor and method of assessment should be the same for both the exposed group and comparison group, and the assessor should be blinded to the exposure of interest. The assessor may also evaluate likely causes for the particular birth defect, such as family history, genetic factors, and/or exposure to known teratogens.28 If the exposure of interest is made available, the assessor may examine the timing of the exposure relative to the origin of the birth defect (to attempt to determine if the timing of the exposure is relevant to the formation of the birth defect).28 Registries can engage the scientific advisory board and/or a subgroup of the board to review each case and the assessor's classification and reach consensus on the classification.

### 17.7 Process of Releasing Findings

#### 17.7.1 Reporting Findings to Regulatory Agencies

FDA considers individual case reports from a pregnancy registry as derived from active solicitation of patient information (FDA 1997), including reports from participants enrolled both prospectively, where the exposure is reported prior to knowledge of the pregnancy outcome, and retrospectively, where the pregnancy outcome is already known at the time the exposure is reported.2 A company sponsor holding marketing authorization for an approved drug or licensed biological product must submit to FDA, within 15 calendar days, reports of pregnancy registry adverse events that are both serious and unexpected by regulatory definition and where a reasonable possibility exists that the drug or biological product caused the adverse event. Current reporting requirements in the regulations consider any congenital anomaly a serious adverse event.

Pregnancy registries conducted independently of any sponsors holding marketing authorizations are not subject to postmarketing regulatory reporting requirements. However, investigators conducting such registries may forward reports of any serious adverse events including congenital anomalies to the sponsor of the medical product or report directly to FDA's MedWatch office (1-800-FDA-1088 or http://www.fda.gov/Safety/MedWatch/default.htm).

Any company conducting a pregnancy registry required by FDA must submit an annual status report to the agency. Companies conducting pregnancy registries not subject to annual reporting requirements are encouraged to include a status report in the periodic safety report. The status/interim report should describe the study design and summarize the status of the planned, initiated, in progress, or completed pregnancy registry conducted by or otherwise obtained by the sponsor during the reporting period. The status report should also provide a descriptive summary of progress to date, interpretation of findings, and appropriate analyses with comments on the clinical significance of the findings. Copies of full reports may be appended, if appropriate. Any publications based on data from the registry should be included.

The registry status report should include the following, presented separately for prospective and retrospective reports:

- Number of pregnant women enrolled to date
- Number of pregnancies with outcome known (stratified by live birth, spontaneous abortions, elective terminations, fetal deaths/stillbirths)
- Number of pregnancies with outcome pending, and number of pregnancies lost to followup (p 16, FDA guidance)2

For pregnancies with known outcomes, line listings (which are tables that organize key information about cases with each row representing one case and each column representing a variable of interest40) and summaries of the following:

- Demographics, obstetrical and medical history of mothers
- Weeks of gestational age at exposure
- Dose and duration of exposure
- Whether multiple gestation
- Weeks of gestational age at completion or termination of pregnancy
- For live births and deaths/stillbirths:
- Small for gestational age
- Preterm delivery
- Congenital anomalies or other fetal abnormalities

Finally, for spontaneous abortions and elective terminations, abnormalities in products of conception, if known.

#### 17.7.2 Reporting to Sponsors

There are no specific rules for reporting events to the sponsor company. The sponsor company negotiates this with the academic center or CRO. Some pregnancy registries have regular (semiannual or annual) data cutoff points and issue corresponding periodic interim reports summarizing the aggregate data. The sponsor can then use this interim report for any regulatory reporting requirements.1 Others, such as the NAAED, have prespecified criteria for release of results for a positive association.33

Most pregnancy registries administered by CROs or academic institutions report all adverse pregnancy outcomes (birth defects, spontaneous fetal losses, induced abortions), and maternal and nondefect fetal events, regardless of attribution or seriousness, to the sponsor within a few business days. Some sponsors only request specific outcomes, or serious and attributable events, reported to them. The sponsor reports these events to regulatory agencies. Pregnancy is not considered an adverse event (AE). The registry might also report spontaneous AEs (not registry-related outcomes) to the sponsor, although these may be received infrequently. If the sponsor requires further information on a pregnancy-related AE, it can contact the registry, which would contact the health care provider. The sponsor follows up on any non-registry cases as needed.

#### 17.7.3 Publication Policy

Some pregnancy registries have formal publication committees.34 In others, such as NAAED, the investigators review plans to publish registry data and conclusions with the independent scientific advisory committee, and a consensus to publish is developed.33 Others simply publish the findings when they have them. Registry results should be published as soon as the number of women in the registry permits, in order to allow dissemination of the results to the scientific and clinical communities.

### 17.8 Role of (Scientific) Advisory Board

An independent scientific advisory committee usually oversees the scientific conduct and analysis of the registry. This committee can advise and participate in the design and establishment of the registry, as well as assist in the review of data, the classification of any birth defects, and the dissemination of information to ensure that results are interpreted and reported accurately. The role and duties of the committee should be specified in the protocol. Members of the committee could include experts in obstetrics, embryology, teratology, pharmacology, epidemiology, pediatrics, clinical genetics, and any relevant therapeutic areas; and consumers representing the disease state being treated; and may include members from the CDC, the National Institutes of Health, academia, and the private sector. The advisory committee might review the registry data, develop consensus statements, provide recommendations on modifications or enhancements to the registry, and/or assist in the dissemination of information and the formulation of strategies to encourage enrollment. In addition to the scientific advisory committee, multicompany-sponsored pregnancy registries may also include a steering committee composed of representatives of the sponsoring pharmaceutical companies.

### 17.9 Stopping Rules

The criteria to determine when to end the study may be predetermined and specified in the protocol. If the registry is conducted by a drug company as a regulatory requirement, the decision as to when to actually end the study is made jointly by the company and the regulatory authority. In other pregnancy registries, it is the scientific advisory committee that decides or contributes to the decision about when to stop. Sometimes, findings from the registry might affect the decision as to whether it should continue.

Criteria for possible discontinuation of a pregnancy registry include the following:

1. Sufficient information has accumulated to meet the scientific objectives of the registry (i.e., numeric targets or predetermined effect size, such as the “no evidence of risk” or “evidence of relative safety” thresholds defined in the newly created Vaccines and Medications in Pregnancy Surveillance System:20 “Estimates of safety cannot be absolute; rather, they reflect the degree of confidence that is consistent with an observation of no increased risk between a given exposure and outcome. As more data are collected over time, power increases; for a null observation, increasing power leads to increasingly narrower confidence bounds and increasing assurance of relative safety.”20 For example, evidence of relative safety might be reached when the upper bound of the 95 percent confidence interval excludes a twofold increased risk.
2. The feasibility of collecting sufficient information diminishes to unacceptable levels because of low exposure rates, poor enrollment, and/or high rates of loss to followup.
3. Other methods of gathering appropriate information, such as case-control surveillance or large health care databases, become achievable or are deemed preferable.2

### 17.10 Multidrug Pregnancy Registries

A multidrug pregnancy registry actively collects information on exposure to various drug therapies for specific diseases, such as the Antiretroviral Pregnancy Registry34 and NAAED.33 In some cases, a general multidrug registry, such as that conducted by a teratogen information service, collects information on drugs for either unrelated or related indications. Multidrug registries have advantages over single-drug registries with respect to both efficiency and economy; they also allow the examination of polytherapy. They may also have the advantage of having readily available comparison groups of pregnant women unexposed to the specific medical product(s) of interest but with the same indication (e.g., disease registries) or exposed to other drugs for the same indication.

Disease pregnancy registries for common conditions in women of childbearing age (e.g., multiple sclerosis) treated with any available drug would make most sense from logistical (avoidance of duplicating efforts), methodological (validity and power), and clinical (comparative safety) points of view. However, their establishment would require collaboration among companies competing for the same therapeutic area, which may be difficult.

### 17.11 Multicenter and Global Registries

Like RCTs, registries can be multicenter, national, or international. Currently, registries are centralized by sponsors, CROs, government agencies, or academic centers; they typically focus on a single drug, multiple drugs within a class, multiple drugs for different indications, or are disease based and evaluate drugs used to treat a particular condition.1 In the future, rather than conducting a new registry for each drug, a global centralized mega pregnancy-exposure registry may exist, guided and coordinated by collaborations among regulatory agencies, pharmaceutical companies, contractor organizations, and academic centers.19 Although appealing, in practice it will be a challenge for this approach to accommodate the case-specific needs for each drug.

In terms of setup, management, and analysis, a locally run registry is very different in scope from a global registry. The latter's geographic scope includes many challenges (e.g., language, culture, time zone, regulatory differences) that must be taken into consideration in the planning process. A distinct feature of a country-specific registry is that the patient population tends to be more homogeneous with respect to demographic characteristics, exposures, length of followup, and diagnosis of outcomes than international registries.

## 18 Advantages of Pregnancy Registries

Pregnancy registries are often the initial proactive step in assessing the safety of use during pregnancy of new drugs after they are first marketed, because they provide a number of advantages over other approaches:1 While many pregnant women use medications, their use of individual drugs can be quite rare.41 By enrolling an exposure group made up only of women who took the medication(s) of interest, pregnancy registries are efficient for evaluating the effects of infrequently used drugs in the population. This is a distinct advantage over other study designs, such as case-control studies and small health care utilization databases, which usually do not have sufficient power to evaluate outcomes following rare exposures.

The longitudinal nature of pregnancy registries allows the estimation of absolute risks of pregnancy outcomes. For example, registries that enroll women before any prenatal testing has been performed can estimate the risk of malformations among infants whose mothers used a drug of interest. This is in contrast to case-control studies that estimate risk relative to that for a reference group. Information about the absolute risk of outcomes is particularly helpful when counseling women who are planning a pregnancy or who have already become pregnant while taking a drug. Prospective enrollment facilitates ascertainment of drug exposures close to the time a medication is actually used and before information about the pregnancy outcome is known. When registries interview pregnant women directly, they can obtain accurate information about the timing in relation to gestational age, dose, frequency, and duration of medication use, as well as covariates, and can therefore reduce exposure misclassification, recall bias, and confounding.

Pregnancy registries can compare the risk of outcomes among women who have used a variety of treatments for a single condition, including different monotherapies, different polytherapy combinations, or no treatment at all. This information is useful both to women and health care providers in making decisions about whether to treat a condition during pregnancy and which of multiple alternate therapeutic strategies to use. An additional advantage is that a single registry can monitor a variety of pregnancy and infant outcomes after medication exposure, including postnatal outcomes.

## 19 Limitations of Pregnancy Registries

The pregnancy registry approach also has a number of limitations. While pregnancy registries are an efficient means to assess rare exposures, they lack the statistical power to evaluate rare outcomes. Most teratogenic exposures do not increase the prevalence of all malformations, but have a more selective effect on individual defects or distinct patterns of defects. Pregnancy registries are powered to detect common outcomes such as the total prevalence of all malformations, and can detect only very large increases in these rarer individual defects or patterns. However, many drugs associated with adverse effects in pregnancy result in only moderate increases in these rarer outcomes. Therefore, pregnancy registries are limited in their ability to detect teratogenic effects on specific malformations with statistical certainty. Nevertheless, registries can generate hypotheses that form the basis of further investigation using complementary approaches, study designs, and data sources.20

Another important limitation of some pregnancy registries is the lack of a comparable reference group. Ideally, a comparison group should be drawn from the same population as women with the exposure of interest, using the same methods for recruitment, enrollment, and ascertainment of outcomes so that both groups have the same baseline risk for adverse pregnancy outcomes. Comparison of registry findings with data from other studies, such as population-based surveillance programs or hospital deliveries, can lead to biased results if the subjects in the reference group have characteristics different from those of the registry participants, or it the methodology for case ascertainment is different. Identifying an appropriate reference group can be particularly difficult for global registries that recruit exposed women from multiple countries with potentially different populations and backgrounds. For registries such as these, a comparable unexposed group may not exist. Even when an internal reference group is recruited, differences between the exposed and unexposed groups with respect to factors such as the indication for the drug or the proportion of subjects lost to followup can affect the validity of the results.

An additional consideration is that findings from a pregnancy registry may not be generalizable to the broader population of all women who use a drug. Enrollment of women in pregnancy registries typically is voluntary and self-selected, and registry participants represent a small proportion of all women who have taken a drug. For these reasons, the characteristics and experience of women who participate in a registry may differ from those of nonparticipants, and these characteristics may modify the effect of the drug.

A final limitation of pregnancy registries is the length of time typically required to enroll sufficient numbers of exposed women to generate stable estimates of pregnancy outcomes. This timeframe can be affected by the frequency of exposure in the general population, and by the methods and extent of recruitment efforts by the registry. Most registries continue for years before publishing final results. This extended period of evaluation before reaching conclusions regarding adverse pregnancy outcomes can be a disadvantage when there are pregnancy outcomes of concern that need to be evaluated quickly or when new therapeutic agents become available.

## 20 Evaluation of Reports From Pregnancy Registries

It is important to critically assess the results and conclusions of reports from pregnancy registries. Key issues to consider are summarized in Table 21–2.

Table 21–2 Issues to consider when evaluating reports from pregnancy registries

Area | Issues
Objectives | What question(s) is the registry attempting to answer? Are the design and methods appropriate to do so?
Background | What condition(s) is the drug used to treat (e.g., chronic vs. episodic)? In what settings is the drug likely to be used (e.g., as primary treatment or as adjuvant therapy with other drugs)? What is the recommended therapeutic dose and duration of use? Is the drug likely to be used off label for conditions other than the stated indication?
Study population | What is the target population from which pregnant women exposed to the drug are drawn? Does the report describe the characteristics of women enrolled in the registry? Could the study subjects differ from women in the target population in ways that would affect the generalizability of the results?
Exposure ascertainment | What are the sources of information about drug exposure (e.g., maternal interviews, physician reports, pharmacy records)? Are these sources likely to provide valid information about how women actually used the drug? Are the exposures ascertained in sufficient detail (e.g., dose, frequency, duration, timing during gestation) to accurately assess the drug's potential effects on the outcome(s) of interests?
Outcome ascertainment | What are the sources of information about pregnancy outcomes, infant and fetal health (e.g., maternal interviews, obstetricians' reports, pediatric records)? Are these sources likely to be knowledgeable about the occurrence of the outcomes being studied? Are outcomes among stillbirths, spontaneous abortions, and elective terminations included? Are the outcomes documented in sufficient detail?
Reference group(s) | What comparison group(s) does the registry use? Is an internal comparison group recruited? Are there potential differences between the exposed and comparison groups that could affect the validity of the findings?
Statistical power | Does the sample size provide sufficient statistical power to meet the objective(s)?
Biases | When did subjects enroll (i.e., gestational age at enrollment for exposed and reference groups)? What proportion of registry enrollees did not complete the study (i.e., were lost to followup)? Do their characteristics differ from those who completed the study in ways that could affect the validity of the results? Are exposed subjects comparable to the reference group? Were the same methods for data collection and outcome definition used in the exposed and reference groups? Are there other possible sources of bias in the results? Are these biases addressed sufficiently in the analyses or in sensitivity analyses?
Results | Does the report provide estimates of the absolute risk of the adverse pregnancy outcomes being studied? Are the results generalizable to the broader population of pregnant women who will use the drug?
Conclusions | Does the report explore possible alternative explanations for the findings? Does the report review and compare findings from other studies that assess the drug's effects during pregnancy, or findings for other drugs used to treat the same condition(s)? Do the registry findings provide information that will be useful to health care providers and women in making clinical decisions about use of the medication and pregnancy management?

## 21 Summary

Well-designed and -executed pregnancy registries are an efficient initial approach to assess the safety of biopharmaceuticals during pregnancy, and can provide data that health care providers can use in treating and counseling patients who are pregnant or wish to become pregnant. Although pregnancy registries are more appropriate to identify or rule out large increases in the risk for malformations than to identify more modest teratogenic risks, they are a valuable tool to establish safety boundaries around risk estimates as data accumulate. Pregnancy registries have some unique characteristics that distinguish them from other registries or types of surveillance. Critical methodological issues to consider in their design include the prospective enrollment of women before the pregnancy outcome is known, inclusion of a comparable reference group, thoughtful assessment of drug exposure, ascertainment of prenatal and postnatal diagnosis, and validation of outcomes. Chance and potential biases should be considered when interpreting results from any observational study. A surveillance program should consider a combination of different sources of data so that associations detected in one study can be replicated or refuted by others.20

## Case Examples for Chapter 21

Case Example 49 Expanding an ongoing pregnancy registry

Description | The Antiretroviral Pregnancy Registry is the oldest ongoing pregnancy exposure registry. This multisponsor, international, voluntary, collaborative registry monitors prenatal exposures to all marketed antiretroviral drugs for potential risk of birth defects.
Sponsors | Abbott Laboratories, Apotex Inc, Aurobindo Pharma Ltd., Boehringer Ingelheim Pharmaceuticals Inc., Bristol-Myers Squibb Company, Cipla Ltd., Gilead Sciences Inc., HEC Pharm, Hetero USA, Janssen Infectious Diseases BVBA, Merck & Co. Inc., Mylan Laboratories, Novartis Pharmaceuticals, Pfizer Inc., Ranbaxy Inc., Roche, Teva Pharmaceuticals, and ViiV Healthcare (represented by GlaxoSmithKline).
Year Started | 1989
Year Ended | Ongoing
No. of Sites | Not site-based; open to all health care providers. Nearly 2,000 health care providers have contributed data to the registry.
No. of Patients | 16,732

#### Challenge

Antiretroviral treatments represent an area of particular concern for monitoring safety in pregnancy. Women may need to take the drugs during pregnancy to manage their own HIV infection and to reduce the risk of transmitting HIV to the infant, but these benefits must be weighed against the risk of teratogenic effects. Because of these factors, it is extremely important for clinicians and patients to understand the risks of using antiretroviral drugs during pregnancy in order to make an informed decision. However, ethical and practical concerns make a randomized trial to gather these data difficult, if not impossible.

In 1989, the first manufacturer of an antiretroviral drug voluntarily initiated a pregnancy exposure registry to track the outcomes of women who had used its product during pregnancy. The purpose of the registry is to collect information on any teratogenic effects of the product by prospectively enrolling women during the course of their pregnancy and following up with them to determine the outcome of the pregnancy. Physicians enroll a patient by providing information on the pregnancy dates, characteristics of the HIV infection, drug dosage, length of therapy, and trimester of exposure to the antiretroviral drug. Information on the pregnancy outcome is gathered through a followup form sent to the physician after the expected delivery date.

In 1993, the registry was expanded to include all antiretroviral drugs, as other manufacturers voluntarily joined the registry once their drugs were on the market. The registry is international in scope and allows any health care provider to enroll a patient who intentionally or unintentionally has used an antiretroviral drug during pregnancy. The U.S. Food and Drug Administration, which has used this registry as a model for new pregnancy registries, now requires participation in the registry for all new and generic antiretroviral drugs.

The year 2012 marks the 20th anniversary of the registry. Since 2006, the registry has more than doubled the enrollment of the first 15 years, increasing enrollment from 6,893 pregnancies in 2006 to 16,732 in 2012. This increase was partly due to the increased number of new antiretroviral medications on the market. In 2006, the registry monitored 28 medications from 8 companies; by 2012, it monitored 36 medications from 18 companies (including manufacturers of both branded and generic products). The registry has also increased enrollment as well as its geographic representation by incorporating the datasets of comparable, completed epidemiological studies. For example, the registry added data on nearly 1,000 women from a study conducted in Brazil and Argentina of antiretroviral-exposed pregnant women who delivered between the years 2002 and 2007.

In addition to this large increase in enrollment, electronic data capture (EDC) was introduced in 2010 as a data collection method for the registry.

In summary, early challenges for the registry included establishing standard processes for monitoring and assessing the safety of drugs during pregnancy. Key challenges in recent years have included managing the methodological and analytic implications of a rapid growth in size and the operational implications of adding EDC.

#### Proposed Solution

To ensure both rigor and consistency early on, the registry put in place predefined analytic methods and criteria for recognizing a potential teratogenic signal. Tools for coding and classifying birth defects were developed for the registry to maximize the likelihood of identifying a teratogenic signal. This unique system groups birth defects by etiology or embryology rather than by general location or category, as does the Medical Dictionary for Regulatory Activities (MedDRA). Grouping like defects together increases the likelihood of detecting a potential signal. The registry also codes the temporal association between timing of exposure and formation of the birth defect, aiding in signal detection.

Specific monitoring criteria were developed for evaluating signals at various levels, including the Rule of Three (the rule that three exposure-specific cases with the same birth defect require immediate evaluation). This rule is based on the statistical principle that the likelihood of finding at least three of any specific defect in a cohort of 600 or fewer by chance alone is less than 5 percent.

In the last few years of the registry's operation, large increases in enrollment required re-evaluation of the adequacy of existing signal detection rules. The Rule of Three continues to serve an important role; however, understanding weak signals is methodologically challenging. Incorporating enrollments from comparable epidemiological studies into the registry population has boosted enrollment, increased cultural diversity, and enhanced signal detection capabilities. Each merger of external data prompts the need to re-examine the potential for selection and ascertainment bias.

Operationally, each new participating manufacturer undergoes a series of trainings and is required to obtain institutional review board approval before participation in the registry. Registry trainings and standard operating procedures are reviewed at biannual steering committee meetings and revised as appropriate.

In expanding the options for data entry into the registry, a hybrid EDC-paper approach was deemed operationally feasible in lieu of an EDC-only approach. This allowed a subset of established reporters to use EDC, while limiting disruption for reporters who preferred to report data on paper CRFs.

#### Results

The registry now contains data on 16,732 prospective pregnancies with exposure to 36 medications from 18 companies. Approximately 40 percent of new enrollments in the registry are made using EDC technology.

Registry data have been used in 13 publications, 9 abstracts, and 25 presentations, and the registry design and operation have been the subject of many publications and presentations. The registry findings can help provide clinicians and patients with information to make informed decisions regarding use of antiretroviral drugs during pregnancy.

#### Key Point

A pregnancy exposure registry can employ continuous quality improvement practices to identify and define key quality processes and keep the registry current and innovative throughout its life cycle. The fact that the registry had established, standard policies and procedures for coding, monitoring, and analysis was critical in incorporating new partners and data sources quickly and easily. Regular review of these policies and procedures is essential to respond to the changing registry environment.

#### For More Information

Antiretroviral Pregnancy Registry Steering Committee. Antiretroviral Pregnancy Registry International Interim Report for 1 January 1989 through 31 January 2012. Wilmington, NC. Registry Coordinating Center. 2012. http://www.apregistry.com/. .

Tilson H, Roberts S, Watts H, et al. The Antiretroviral Pregnancy Registry: A 20th anniversary celebration. Pharmacoepidemiology and Drug Safety. 2011;20(S1):S190. .

Tilson H, Doi PA, Covington DL, et al. The antiretrovirals in pregnancy registry: A fifteenth anniversary celebration. Obstet Gynecol Surv. 2007;62:137-48. [pmid: 17229330]. .

Covington D, Tilson H, Elder J, et al. Assessing teratogenicity of antiretroviral drugs: monitoring and analysis plan of the Antiretroviral Pregnancy Registry. Pharmacoepidemiol Drug Saf. 2004;13:537-45. [pmid: 15317035]. .

Scheuerle A, Covington D. Clinical review procedures for the Antiretroviral Pregnancy Registry. Pharmacoepidemiol Drug Saf. 2004;13:529-36. [pmid: 15317034]. .

Case Example 50 Using a pregnancy registry to detect major teratogenicity

Description | The International Lamotrigine Pregnancy Registry was established to monitor for the signal of major teratogenicity following in utero exposure to lamotrigine.
Sponsor | GlaxoSmithKline
Year Started | 1992
Year Ended | 2010
No. of Sites | Not applicable; health care providers reported lamotrigine exposure during pregnancy and subsequent pregnancy outcomes on a voluntary basis.
No. of Patients | 1,558

#### Challenge

Lamotrigine is a second-generation anticonvulsant therapy, widely indicated for the treatment of epilepsy. Lamotrigine was approved in the United States for the treatment of epilepsy in 1994 and for the treatment of bipolar disorder in 2003. In 1992, following the approvals of lamotrigine in several different European countries, the International Lamotrigine Pregnancy Registry was established to monitor the frequency of major teratogenicity following in utero exposure to lamotrigine. Major congenital malformation (MCMs), identified after birth and before hospital discharge, was the primary outcome evaluated by the registry. The U.S. Centers for Disease Control and Prevention's Metropolitan Atlanta Congenital Defects Program case definition was used to classify MCMs. Due to the rarity of the outcome, the registry needed to enroll enough limotrigine-exposed patients in order to have adequate statistical power to detect changes in MCM frequencies.

#### Proposed Solution

The registry targeted an enrollment of 1,000 limotrigine-exposed pregnant women. Prospective reporting early in pregnancy was encouraged. The registry also received and reviewed retrospective reports, defined as those for which the pregnancy outcome was known at the time of reporting. Due to successful patient enrollment, the registry closed to new prospective enrollments in June 2009, and continued to follow up with existing enrollments through March 2010. The results of the International Lamotrigine Pregnancy Registry were compared descriptively against the results of other ongoing anti-epileptic drug (AED) pregnancy registries. While major teratogenicity was evaluated, the registry was not powered to determine the frequency of specific malformation types; surveillance for specific types using the European Congenital Anomalies and Twins Registers (EUROCAT) network is planned.

#### Results

At registry closure, over 1,500 birth outcomes involving first-trimester monotherapy exposure had been evaluated during the 18-year registry period. The registry was thus adequately powered to meet its primary objective, to determine whether the overall rate of major malformations was increased among the offspring of exposed women. The registry did not detect an appreciable increase in the outcome of MCMs overall. Over an 18-year period, 35 infants with MCMs were observed among 1,558 first-trimester monotherapy exposures: 2.2% (95% CI, 1.6 to 3.1). This was similar to estimates from general population-based cohorts and no pattern of malformation frequency by dose was observed. However, the registry was not powered to exclude increases in the rates of specific defects.

First-trimester monotherapy results from the registry were consistent with several other ongoing AED pregnancy registries, such as the North American Antiepileptic Drug Pregnancy Registry (2.3%, 95% CI, 1.3 to3.8) and the EURAP international pregnancy registry (2.9%, 95% CI 2.1 to 4.1). Monitoring of specific malformations among lamotrigine-exposed pregnancies will continue through case-control surveillance in the EUROCAT network.

#### Key Point

A drug-specific pregnancy registry can provide valuable information about risks of major congenital malformations following in utero exposure; however, it may take several years to collect enough exposed patients to detect a signal of teratogenicity with sufficient statistical power. For such rare outcomes, accumulating data over long periods of time and from multiple registries is advantageous to monitoring the safety of medical treatments used in pregnancy.

#### For More Information

Cunnington MC, Weil JG, Messenheimer JA, et al. Final results from 18 years of the International Lamotrigine Pregnancy Registry. Neurology. May. 24. 2011;76(21):1817-23. [pmid: 21606453]. .

Case Example 51 Implementing a non-mandated pregnancy registry

Description | The Global Gleevec^®^/Glivec^®^ & Tasigna^®^ Pregnancy Exposure Registry is an international, prospective, observational registry of women and their offspring exposed to Gleevec/Glivec (imatinib) and/or Tasigna (nilotinib) during pregnancy or within 6 months prior to pregnancy. The primary objective of the registry is to monitor pregnancies exposed to Gleevec/Glivec or Tasigna (tyrosine kinase inhibitors to treat some cancers) to assess the prevalence of birth defects. Secondary objectives include determining the impact of interrupted treatment on maternal disease status and assessing infant development around 12 months postdelivery.
Sponsor | Novartis
Year Started | 2011
Year Ended | Ongoing
No. of Sites | 4
No. of Patients | 5 (expected enrollment of 150)

#### Challenge

Chronic myelogenous leukemia and gastrointestinal stromal tumor are rare oncologic diseases. Since the approval of Gleevec/Glivec in 2001, life expectancy for these diseases has substantially improved and treatment is now considered chronic. Tasigna, approved for chronic myelogenous leukemia treatment in 2007, is shown to have superior efficacy compared with Gleevec/Glivec. Patients of child-bearing age are now contemplating reproductive opportunities that would not have been possible previously, and are requesting information about the safety and effectiveness of these treatments during pregnancy. The sponsor sought to address this unmet medical need by collecting data on pregnancy outcomes and on the disease status of pregnant women who were exposed to Gleevec/Glivec or Tasigna during pregnancy.

Pharmaceutical companies typically establish pregnancy registries when they are mandated to do so by regulatory authorities. This registry is voluntary and was not mandated by regulatory authorities, and consequently the sponsor experienced challenges in study startup and in enrollment. Regulatory requirements in countries outside the United States evolved during startup, and these changes required revisions to study design. Additionally, both Gleevec/Glivec and Tasigna are classified by the U.S. Food and Drug Administration (FDA) as pregnancy category D, and the prescribing information carries a warning that these drugs should not be administered to pregnant women. Thus, the sponsor was careful to design an awareness campaign that did not promote exposure during pregnancy.

Most existing pregnancy registry models focus primarily on collecting birth outcomes and do not collect maternal disease status or postpartum data. Since this registry was not mandated, and information on maternal health as well as birth outcomes was desired, a novel model was needed.

#### Proposed Solution

The registry was launched in the United States in 2011 and in Russia, the Netherlands, and Denmark in 2012. The sponsor adopted a national coordinator (NC) model for the registry. The NC is a domestic entity responsible for submitting the protocol to the appropriate regulatory authority for approval and for facilitating the collection of registry data from multiple sources (e.g., oncologists, hematologists, obstetricians, pediatricians). In the United States, the NC is a contract research organization; outside the United States, the NC is a participating physician who has agreed to assume the above responsibilities. Data are collected on maternal disease status at 3 time points: enrollment, pregnancy outcome, and about 12 months postdelivery according to local standard of care. Data are also collected on the fetus/infant at pregnancy outcome and about 12 months of age.

A Web site was constructed that provides information about the registry and instructs patients (only in the United States) and providers (globally) on how to enroll into the registry. The sponsor worked closely with regulatory authorities to ensure that the information presented on the Web site is educational and not promotional in nature. Patient recruitment is facilitated through the existing pregnancy reporting infrastructure in the sponsor's safety department; U.S. health care providers calling to report pregnancies are invited to enroll eligible patients into the registry. Additionally, collaborating with patient advocacy groups and preparing durable materials facilitates registry awareness.

#### Results

The sponsor encountered unanticipated delays and challenges from regulatory authorities, possibly because non-mandated pregnancy registries are unprecedented. Recent European Medicines Agency legislation expanding the safety reporting requirement for noninterventional studies has necessitated further revisions to the protocol and case report form. Work is continuing on expanding the registry to other countries.

Five patients have been enrolled to date, and this number is expected to increase when the registry's Web site and awareness materials are approved by FDA for use in the United States.

#### Key Point

Pregnancy registries not mandated by regulatory authorities present unique operational challenges. Beginning a study in locations with a favorable regulatory environment may help minimize delays in startup and allow sponsors to apply lessons learned before expanding the registry to other locations. Staying current with regulatory requirements in long-term pregnancy registries is critical to remaining compliant. When collecting data from several different sources (e.g., patients and multiple providers), consider an operational model that centralizes the responsibility for data collection and for health authority and ethics committee submission and approval.

#### For More Information

Juma M, Ericson S, Eng D, et al. Prospective, observational registry of branded imatinib and nilotinib exposure in pregnant women: voluntary post-authorization safety study. Poster presented at 2012 annual meeting of the American Society of Clinical Oncology (ASCO). Abstract # TPS6638. .

Juma M, Ericson S, Eng DF, et al. Prospective, observational registry of branded imatinib and nilotinib exposure in pregnant women: Voluntary post-authorization safety study. Poster presented at the 2011 ASCO annual meeting. Abstract #82968. .

Case Example 52 Using proactive awareness activities to recruit patients for a pregnancy exposure registry

Description | The Ribavirin Pregnancy Registry is a component of the Ribavirin Risk Management Program. It was designed to evaluate the association between ribavirin and birth defects occurring in the offspring of female patients exposed to ribavirin during pregnancy or the 6 months prior to conception, as well as female partners of male patients exposed to ribavirin during the same time period. The registry collects prospective, observational data on pregnancies and outcomes following pregnancy exposure to ribavirin.
Sponsor | Aurobindo Phama USA; Genentech, Inc.; Sandoz Pharmaceuticals Inc.; Schering Corporation, a subsidiary of Merck & Co. Inc.; Teva Pharmaceuticals USA, Inc.; Three Rivers Pharmaceuticals, LLC; Zydus Pharmaceuticals (USA) Inc.
Year Started | 2003
Year Ended | Ongoing
No. of Sites | Not applicable (population-based)
No. of Patients | Approximately 230 evaluable pregnancies

#### Challenge

Ribavirin is used in combination with interferon alfa or pegylated interferon alfa for the treatment of hepatitis C. Chronic hepatitis C presents a serious health concern for approximately three million Americans, as the infection, if left untreated, can lead to end-stage liver disease, primary liver cancer, and death. When used as part of a combination therapy, ribavirin can significantly increase both viral clearance and liver biopsy improvement for hepatitis C patients.

However, ribavirin showed teratogenic properties in all animal models tested, making pregnancy exposure a concern. There are minimal data on ribavirin exposure in human pregnancies. Thus, the U.S. Food and Drug Administration (FDA) designated ribavirin as a Pregnancy Category X product based on the animal data, and ribavirin carries product label warnings against becoming pregnant.

Despite the product warnings, pregnancies continue to occur. Health care professionals have insufficient data on the teratogenic properties of ribavirin in humans to counsel pregnant women exposed to ribavirin either during pregnancy or in the 6 months prior to conception. The registry was established to gather prospective data on ribavirin exposure in pregnancy and pregnancy outcomes to better understand the actual risk.

The registry collects data on direct exposures through the pregnant female and indirect exposures through her male sexual partner. Health care providers, pregnant patients, or pregnant patients' male sexual partners may submit data to the registry. The registry collects minimal, targeted data at each trimester and at the outcome of the pregnancy through the obstetric health care providers. For live births, the registry collects data at 6 months and 12 months after the birth by contacting the pediatric health care provider.

To gather data on these patients, the registry needed to develop proactive awareness activities to make patients and providers aware of the program and encourage enrollment without promoting ribavirin use during pregnancy.

#### Proposed Solution

The registry team developed a multipronged approach to recruiting patients. First, the team developed a comprehensive Web site with information for patients and providers. The Web site contains fact sheets, data forms, information on how to participate, and contact information. The site also contains a complete slide set that health care providers can use for teaching activities.

While the site contains detailed information on the scientific reasons for the registry, the tone and content of the Web site are patient friendly, making it a good resource for both potential patients and providers.

Next, the team began targeting professional service groups whose members might treat patients with ribavirin exposure during pregnancy. The groups included hepatologists, gastroenterologists, obstetricians, and pediatricians. By contacting the groups' leadership and sending individualized mailings to members, the team hoped to raise awareness across a broad spectrum of providers. The team communicated with nursing groups, including publishing an article in a nursing journal targeted to gastroenterology nurses, with the goal of utilizing the nurse's role as a patient educator. As a result of these efforts, the American Gastroenterological Association placed a link for the registry Web site on its Web site, and the American Association for the Study of Liver Diseases posted on its Web site an expert opinion piece written by the former registry advisory board chair.

The registry team also raised awareness among professional groups by attending conferences. In 2005, the team presented a poster about the registry, including some information on demographics and program objectives, at the Centers for Disease Control and Prevention National Viral Hepatitis Prevention Conference. In 2009, the team presented a poster at the International Society for Pharmacoepidemiology and in 2010 at the conference of the Teratology Society.

In 2010, to expand awareness efforts to health care providers, the registry published results after five years of enrollment, even though the targeted sample size had not been reached. In 2011, the registry developed an article for Peri-FACTS, a continuing education eJournal for OB/GYNs, nurses, and other health care providers, sponsored by the University of Rochester. Beginning in 2012, the registry began providing the executive summary of its annual interim report to health care providers upon request; this summary provides the most up-to-date snapshot of registry activity.

To raise awareness among patients, the team talked to hepatitis C patient advocacy groups. The registry gained exposure with patients when one patient group wrote an article about the registry for its newsletter and included the registry phone number on its fact sheet. This effort led to many patient-initiated enrollments, despite the lack of patient incentives. In working with patients, the registry has found that emphasizing the goal, which is to gather information to help future patients make better decisions, resonates with patients. Most patients submit data to the registry over the phone, and the rapport that the interviewers have developed with patients has helped to reduce the number of patients who are lost to followup.

In addition to targeting providers and patients directly, the team enlisted the help of public health agencies, since the registry has a strong public health purpose. Registry Web links are posted on the Web sites of the FDA's Office of Women's Health and the Department of Veterans Affairs. A description of the registry is posted on ClinicalTrials.gov.

The team also reviewed the registry process to identify potential barriers to enrollment. Under the initial rules for giving informed consent, the registry call center contacted patients and asked them if they were interested in participating. If patients agreed to participate over the phone, the call center sent a package of information through the mail, including an informed consent document, which the patients needed to sign and return before they could enroll. While many patients agreed to participate over the phone, a much smaller number actually returned the informed consent document. The team identified the process of obtaining written informed consent as a key barrier to enrollment.

After discussions with FDA, the registry team and FDA approached the study institutional review board about receiving a waiver of written informed consent because of the public health importance of the registry. The board agreed that oral consent over the phone would be sufficient for this study. Now, the call center can complete the enrollment process in a single step, as they can obtain oral consent over the phone and then proceed with the interview. This change improved and streamlined the enrollment process and significantly increased the number of participants in the registry.

Throughout all of these recruitment activities, the registry team has emphasized that the purpose of the registry is to answer important safety questions for the benefit of future patients and providers. By focusing on the public health purpose of the registry, the team has been able to encourage participation from both patients and providers. The team has also found that a key element of their recruitment strategy is their detailed awareness plan, which calls for completing awareness activities monthly. Because the leadership and membership of professional groups change and new patients begin taking ribavirin, the team has found that continual awareness activities are important for keeping patients and providers aware of the registry.

#### Results

Through proactive awareness activities, the registry team has generated interest in the project and enrolled approximately 230 exposed pregnancies with outcome information to date. The streamlined oral consent process led to increased enrollment.

#### Key Point

Recruitment activities may include working with professional groups, contacting patient groups, targeting public health agencies, producing publications, and using a Web site to share information. Once recruitment and enrollment have begun, the registry team may need to re-evaluate the process to identify any potential barriers to enrollment if enrollment is not proceeding as planned. If a registry has an ongoing enrollment process, a plan to continually raise awareness about the registry is an important part of the recruitment plan.

#### For More Information

Roberts S. Assessing ribavirin exposure during pregnancy: the Ribavirin Pregnancy Registry. Gastroenterol Nurs. 2008;31(6):413-7. [pmid: 19077835]. .

Roberts SS, the Scientific Advisory Board of the Ribavirin Pregnancy Registry. The Ribavirin Pregnancy Registry is Established. Poster presented at the CDC's National Viral Hepatitis Prevention Conference. Washington, DC. December 5-9, 2005. .

Roberts SS, McKain LF, Covington DL, et al. Paternal exposures and birth defects: overlooked or unnecessary?. Pharmacoepidemiology and Drug Safety. 2009;18:S77. .

Roberts SS, Miller RK, Jones JK, et al. The Ribavirin Pregnancy Registry: Findings after 5 Years of Enrollment, 2003-2009. Birth Defects Res A Clin Mol Teratol. 2010;88:551-9. [pmid: 20564430]. .

Miller RK, Roberts S, Chambers C, et al. Safety of medications during pregnancy: the importance of prospective studies, pregnancy registries, and health care provider collaboration. Peri-Facts, Case 942. University of Rochester. May. 2011. .

## References for Chapter 21

1 Kennedy DL, Uhl K, Kweder SL. Pregnancy Exposure Registries. Drug Safety. 2004;27:215-28. [pmid: 15003034].
2 Guidance for industry: establishing pregnancy exposure registries. 2002. http://www.fda.gov/downloads/Drugs/GuidanceComplianceRegulatoryInformation/Guidances/ucm071639.pdf. June 2011.
3 Wyszynski D. Pregnancy Exposure Registries: Academic Opportunities and Industry Responsibility. Birth Defects Research Part A: Clinical and Molecular Teratology. 2009;85:93-101.
4 List of pregnancy registries. http://www.fda.gov/ScienceResearch/SpecialTopics/WomensHealthResearch/ucm134848.htm.
5 Guideline On The Exposure To Medicinal Products During Pregnancy: Need For Post-Authorisation Data. Committee for Medicinal Products for Human Use. 2005. 2005. http://www.tga.gov.au/pdf/euguide/phvwp31366605en.pdf. June 2011.
6 FDAAA. US Food and Drug Administration Amendments Act (FDAAA) of 2007, Pub. L. No. 75-711, 52 Stat. 1040 (1938) as amended. 2007.
7 Merkatz R, Temple R, Sobel S, et al. Women in clinical trials of new drugs. A change in Food and Drug Administration Policy. New England Journal of Medicine. 1993;329:292-6. [pmid: 8305004].
8 Howard T, Tassinari M, Feibus K, et al. Monitoring for teratogenic signals: Pregnancy registries and surveillance methods. Am J Med Genet C Semin Med Genet. 2011;157:209-14. [pmid: 21766431].
9 Finer L, Henshaw S. Disparities in Rates of Unintended Pregnancy In the United States, 1994 and 2001. Perspectives on Sexual and Reproductive Health. 2006;38:90-6. [pmid: 16772190].
10 Wilson JG. Evaluation of human teratologic risk in animals. Lee DH, Hewson EW, Okun D, editors. Environment and birth defects. First ed. New York and London. Academic Press. 1973:146-60.
11 Holmes L. Human teratogens: update 2010. Birth Defects Research Part A: Clinical and Molecular Teratology. 2011;91(1):1-7.
12 McAdams M, Staffa J, Dal Pan G. Estimating the extent of reporting to FDA: a case study of statin-associated rhabdomyolysis. Pharmacoepidemiol & Drug Safety. 2008;17(3):229-39.
13 Wysowski D, Swartz L. Adverse drug event surveillance and drug withdrawals in the United States, 1969–2002: the importance of reporting suspected reactions. Archives of Internal Medicine. 2005;165(12):1362-9.
14 Mathis L, Iyasu S. Safety monitoring of drugs granted exclusivity under the Best Pharmaceuticals for Children Act: what the FDA has learned. Clinical Pharmacology and Therapeutics. 2007;82(2):133-4. [pmid: 17632537].
15 Werler M, Louik C, Mitchell A. Case-control studies for identifying novel teratogens. Am J Med Genet C Semin Med Genet. Aug. 15. 2011;157C(3):201-8. [pmid: 21766434].
16 Schneeweiss S, Avorn J. A review of uses of health care utilization databases for epidemiologic research on therapeutics. Journal of Clinical Epidemiology. 2005;58(4):323-37. [pmid: 15862718].
17 Charlton RA, Cunnington M, de Vries CS, et al. Data Resources for Investigating Drug Exposure during Pregnancy and Associated Outcomes. The General Practice Research Database (GPRD) as an Alternative to Pregnancy Registries. Drug Safety. 2008;31:39-51. [pmid: 18095745].
18 Andrade S, Davis R, Cheetham TC, et al. Medication Exposure in Pregnancy Risk Evaluation Program. Matern Child Health. Oct. 2012;16(7):1349-54.
19 Honein MA, Paulozzi LJ, Cragan JD, et al. Evaluation of selected characteristics of pregnancy drug registries. Teratology. 1999;60:356-64. [pmid: 10590397].
20 Mitchell AA. Systematic Identification of Drugs That Cause Birth Defects—A New Opportunity. New England Journal of Medicine. 2003;349:2556-9. [pmid: 14695418].
21 ISPE. Guidelines for good pharmacoepidemiology practices (GPP). Pharmacoepidemiol & Drug Safety. 2008;17:200-8.
22 deMoor C, Covington D, Golembesky A. Differing Strategies for Analyzing Multiple Gestation Pregnancies in Pregnancy Registries: Impact on Birth Defect Rates. Pharmacoepidemiol & Drug Safety. 2010;19(Supplement 1):S124.
23 Cragan JD, Gilboa SM. Including Prenatal Diagnoses in Birth Defects Monitoring: Experience of the Metropolitan Atlanta Congenital Defects Program. Birth Defects Research Part A: Clinical and Molecular Teratology. 2009;85:20-9.
24 Reiff_Eldridge R, Heffner CR, Ephross SA, et al. Monitoring pregnancy outcomes after prenatal drug exposure through prospective pregnancy registries: A pharmaceutical company commitment. American Journal of Obstetrics and Gynecology. 2000;182:159-63. [pmid: 10649172].
25 Tabacova S, Little R, Tsong Y, et al. Adverse pregnancy outcomes associated with maternal enalapril antihypertensive treatment. Pharmacoepidemiol & Drug Safety. 2003;12:633-46.
26 Chambers CD, Johnson KA, Dick LM, et al. Birth outcomes in pregnant women taking fluoxetine. New England Journal of Medicine. 1996;335:1010-5. [pmid: 8793924].
27 Chambers C, Hernández-Díaz S, Van Marter L, et al. Selective Serotonin-Reuptake Inhibitors and Risk of Persistent Pulmonary Hypertension of the Newborn. New England Journal of Medicine. 2006;354:579-87. [pmid: 16467545].
28 Briggs GG, Polifka J, Committee OR. Better Data Needed from Pregnancy Registries. Birth Defects Research Part A: Clinical and Molecular Teratology. 2009;85:109-11.
29 Correa A, Cragan J, Kucik J, et al. Reporting birth defects surveillance data 1968-2003. Birth Defects Research Part A: Clinical and Molecular Teratology. 2007;79:65-86.
30 Rothman KJ, Ray W. Should cases with a known cause of their disease be excluded from study?. Pharmacoepidemiology & Drug Safety. 2002;11:11-4. [pmid: 11998545].
31 Dolk H, Loane M, Garne E. The prevalence of congenital anomalies in Europe. Adv Exp Med Biol. 2010;686:349-64. [pmid: 20824455].
32 Chambers C, Braddock SR, Briggs GG, et al. Postmarketing surveillance for human teratogenicity: A model approach. Teratology. 2001;64:252-61. [pmid: 11745831].
33 Holmes L, Wyszynski D, Lieberman E. The Antiepileptic Drug Pregnancy Registry: a six year experience. Archives of Neurology. 2004;61:673-8. [pmid: 15148143].
34 Covington D, Tilson H, Elder J, et al. Assessing teratogenicity of antiretroviral drugs: monitoring and analysis plan of the Antiretroviral Pregnancy Registry. Pharmacoepidemiol & Drug Safety. 2004;13:537-45.
35 Hernán MA, Hernández-Díaz S, Werler MM, et al. Causal knowledge as a prerequisite for confounding evaluation. An application to birth defects epidemiology. American Journal of Epidemiology. 2002;155:176-84. [pmid: 11790682].
36 Hernán MA, Hernández-Díaz S, Robins JM. A structural approach to selection bias. Epidemiology. 2004;15(5):615-25. [pmid: 15308962].
37 Hernández-Díaz S, Schisterman EF, Hernán MA. The birth weight “paradox” uncovered?. American Journal of Epidemiology. 2006;164:1115-20. [pmid: 16931543].
38 Editors. The registration of observational studies-when metaphors go bad. Epidemiology. 2010;21:607-20. [pmid: 20657291].
39 Roberts SS, Covington D. Pregnancy exposure registries: streamlining regulatory requirements to increase enrollment. Pharmacoepidemiol Drug Saf. 2005;15(Suppl 2).
40 MacDonald PDM. Methods in Field Epidemiology. Burlington, MA. Jones & Bartlett Learning. 2012:63.
41 Mitchell AA, Gilboa SM, Werler MM, et al. Medication use during pregnancy, with particular focus on prescription drugs: 1976-2008. Am J Obstet Gynecol. Jul. 2011;205(1):51 e1-8. [pmid: 21514558].