# Recruiting and Retaining Participants in the Registry

## 1 Introduction

Recruitment and retention of participants are essential elements in the design and operation of a registry. Registries are often intended to be representative of a certain population of patients and reflective of the practices of certain providers and geographic areas. The problems commonly associated with clinical studies—such as difficulties with patient enrollment, losses to followup, and certain sites contributing the majority of patients—can also have profound consequences on validity of registry data. When registry patients are not representative of the target population, the value of the results is diminished. For example, in regard to policy determinations, the enrolled sites or providers must be representative of the types of sites and providers to which the policy determination would apply in order for the results of the registry to be generalizable. Differences in how effectively sites enroll or follow patients can skew results and overly reflect the sites with the most data. This oversampling within a particular site or location must also be considered in sample size calculations. If the sample size of a key unit of analysis (patient, provider, or institution) is not sufficient to detect a clinically important difference, the validity of the entire registry is weakened. (See Chapters 3 and 13.)

Well-planned strategies for enrollment and retention are critical to avoiding these biases that may threaten registry validity. Because registries typically operate with limited resources and with voluntary rather than mandatory participation, it is particularly important to balance the burdens and rewards of participation in the registry. The term “voluntary” in this context is intended to mean that participation in the registry by either providers or patients is not mandated (e.g., by the U.S. Food and Drug Administration), nor is participation required as a necessary condition for a patient to gain access to a health care product or for a provider to be eligible for payment for a health care service.

Registries that are not voluntary have different drivers for participation. In general, the burden of participation should be kept as low as possible, while the relative rewards, particularly nonmonetary rewards, should be maximized. As described in Chapters 2 and 4, minimizing burden typically starts with focusing on the key goals of the registry.

Building participation incentives into a registry should also be included in the planning phase. A broad range of incentives—spanning a spectrum from participation in a community of researchers, to access to useful data or quality improvement benefits, to continuing medical education, to public recognition or certification, to payments or access to patients—have been used in registries. The ability to offer certain incentives (e.g., linking payment for a service to participation in a registry or access to patients) may be available only to certain registry developers (e.g., payers, licensing entities). Many registries incorporate multiple types of incentives, even when they pay for participation. Monetary incentives (e.g., from payers or sponsors) are very helpful in recruiting sites. However, because the payments should not exceed fair market value for work performed, registries cannot solely rely on these incentives. A number of nonmandated registries have achieved success in recruitment and retention by providing a combination of ethical incentives that are tailored to and aligned with the specific groups of sites, providers, and patients that are asked to participate. (See Case Examples 20, 21, 22, and 23.)

## 2 Recruitment

Depending on the purpose of a registry, recruitment may occur at any of three levels: facility (e.g., hospital, practice, and pharmacy), provider, or patient. While recruitment at these levels is frequently part of a design to accrue a sufficient number of patients for sample size purposes, such as for a safety registry, the individual levels may also constitute potential units of analysis (and as such, may further affect sample size, as discussed in Chapter 3, Section 8). As an example, a registry focused on systems of care that is examining both hospital system processes and patient outcomes might need to consider characteristics of the individual patients, the providers, and/or the places where they practice (i.e., clusters). If the question is about the practices of orthopedic surgeons in the United States, the registry will be strengthened by describing the number and characteristics (e.g., age, gender, and geographic distribution) of U.S. orthopedic surgeons, perhaps by citing membership data from the American Academy of Orthopedic Surgeons. This will allow documentation of the similarities and differences in the characteristics of the surgeons participating in the registry compared with the target population. (See Chapter 3, Section 7.)

### 2.1 Hospital Recruitment

A hospital or health system may choose to participate in a patient registry for many reasons, including the research interest of a particular investigator or champion, the ability of the hospital to achieve other goals through the registry (such as requirements for reimbursement, certification, or recognition), or the general interest of the particular institution in the disease area (e.g., specialty hospitals). Increasingly, external mandates to document compliance with practice standards provide an incentive for hospitals to participate in registries that collect and report mandatory hospital performance or quality-of-care data. For example, a number of registries allow hospitals to document their performance to meet the Joint Commission requirements for hospital accreditation.1 Hospitals in the United States must submit these data to maintain accreditation. Therefore, hospital administrators may be willing to supply the staff time to collect these data without additional financial incentives from the registry sponsor, provided that registry participation allows the hospital to meet external quality-of-care mandates. In other cases, participation in a quality monitoring or health system surveillance registry may be required by payers or governments for reimbursement, differential payments, or patient referrals under various programs, ranging from the Centers for Medicare & Medicaid Services (CMS) public reporting initiative, to centers of excellence programs, to pay-for-performance programs. One particular example, CMS's Coverage With Evidence Development programs,2 which may require participation in a registry for the center or provider to qualify for payment for a procedure, can have a dramatic impact on registry participation. Registry participation requirements have existed for implantable cardioverter defibrillators for preventing sudden cardiac death in heart failure, for bariatric surgery, for positron emission tomography scan use in cancer, and for other procedures and devices. These requirements have rapidly resulted in high participation rates for registries meeting them.

The presence of quality assurance departments in U.S. hospitals provides an infrastructure for participation in many hospital-based registries, and these departments are therefore a natural target for recruiting. However, hospital size, service line (e.g., disease-specific centers), and competing activities may limit institutional interest. The American Hospital Association database provides a valuable resource for identifying hospitals by key characteristics, including hospital ownership, number of beds, and the presence of an intensive care unit.

Table 10–1 summarizes the key factors for successful hospital recruitment, and lists specific methods that might be used to recruit hospitals. While programs need not incorporate all of these characteristics or use all of these methods, successful programs typically incorporate several.

Table 10–1 Hospital recruitment

Keys to hospital recruitment | - The condition being studied satisfies one of the hospital's quality assurance mandates. Sufficient funds, data, or other benefits will be realized to justify the effort required to participate.; - The confidentiality of the hospital's performance data is ensured, except to the extent that the hospital elects to report it.; - Clinically relevant, credible, timely, and actionable self-assessment data—ideally, data that are risk adjusted and benchmarked—are provided back to the hospital to help it identify opportunities for enhancing patient care outcomes.; - High-profile hospitals (regional or national) are participating in the registry.; - Burden is minimized.; - Participation assists the hospital in meeting coverage and reimbursement mandates, gaining recognition as a center of excellence, or meeting requirements for pay-for-performance initiatives.
Methods of hospital recruitment | - Identify eligible hospitals from the American Hospital Association database.; - Use stakeholder representatives to identify potentially interested hospitals.; - Enroll hospitals through physicians who work there and are interested in the registry.; - Use invitation letters or calls to directors of quality assurance or the chief of the clinical department responsible for the condition targeted by the registry.; - Ask physician members of an advisory board (if applicable) to network with their colleagues in other hospitals.; - Reach out to physicians or hospital administrators through relevant professional societies or hospital associations.; - Leverage mandates by external stakeholders, including third-party payers, health plans, or government agencies.

### 2.2 Physician Recruitment

A physician practice may or may not choose to participate in a voluntary registry for many reasons. As with hospitals, these reasons can include the research interests of the physician and the ability of the practice to achieve other goals through the registry (such as reimbursement or recognition). When deciding to participate, physicians often focus on several concerns:

- Relevance: Does the registry have meaning for the practice and patients?
- Trust: Are the registry leaders credible? Are the goals clearly stated?
- Risks: Will confidentiality be maintained? Are patient records secure?
- Effort: Will the amount of effort expended be fairly compensated?
- Disruption: Will participation disrupt workflow of the staff?
- Value: What benefits will be derived from participation? Will it improve the care provided? Will it enhance the evidence base for future practice?

Physicians who manage only a few patients per year with the disease that is the subject of the registry are less likely to be interested in enrolling their patients than physicians who see many such patients—unless the disease is rare or extremely rare, in which case the registry may be of great interest.

Because most registries are voluntary and physicians in nonacademic practice settings may have less infrastructure and staff available to enroll their patients, recruitment of representative physicians is a major challenge for registries that aim to compare physician practices across a full spectrum of practice settings. In general, community-based physicians are less well equipped than hospital-based or academic physicians to collect data for research studies because they work in busy practices geared to routine clinical care rather than research. To increase recruitment of nonacademic physicians, it can be helpful to clearly explain the purpose and objectives of the registry; how registry data will be used; and, specifically, that individual results will not be shared (except at the direction of the physician) or published, and that registry outcomes data will be released only in large aggregates that protect the identities of individual hospitals, physicians, and patients. In addition, any incentives should be clearly articulated.

Table 10–2 describes the key factors for successful physician recruitment and lists several methods that might be used for recruiting physicians.

Table 10–2 Physician recruitment

Keys to physician recruitment | - The condition being studied is part of the physician's specialty.; - The registry is a valuable scientific endeavor.; - The registry is led by respected physician opinion leaders.; - The registry is endorsed by leading medical, government, or patient advocacy organization(s).; - The effort needed to recruit patients and collect and submit data is perceived as reasonable.; - Useful practice pattern and/or outcome data are provided.; - The registry meets other physician data needs, such as maintenance of certification requirements, credentialing requirements, or quality-based, differential, reimbursement payment programs (pay-for-performance).
Methods of physician recruitment | - Purchase mailing lists from physician specialty organizations.; - Ask opinion leaders in the field to suggest interested colleagues.; - Partner with local and national medical societies or large physician hospital organizations.; - Use stakeholder representatives to identify interested physicians.; - Recruit and raise awareness at conferences.; - Advertise using email and the Web.; - Register in the Registry of Patient Registries (RoPR) to increase awareness.; - Leverage practice-based research networks.

### 2.3 Vetting Potential Hospital and Physician Participants

Once potential hospital or physician participants have been identified, it is important to vet them to ensure that the registry is gathering the appropriate mix of data. Issues to consider when vetting potential participants include—

- Representativeness
- Hospital characteristics (e.g., bed size, geographic location)
- Physician characteristics (e.g., specialty training)
- Practice setting (health maintenance organization [HMO], private practice)
- Ability to recruit patients
- Volume of target cases
- Internal resources
- Availability of a study coordinator
- Availability of Internet connectivity for studies with electronic data capture
- Prior performance, including reliability and accuracy of data entry

### 2.4 Patient Recruitment

Patients may be recruited based on the judgment of the physician who provides their care; the diagnosis of a disease; receipt of a procedure, operation, device, or pharmaceutical; membership in a health insurance plan; or membership in a group of individuals who have a particular exposure. Recruitment of patients by the physician who is providing their care is one of the most successful strategies. The direct involvement in and support of the registry by their personal physicians is an important factor for patients.

Since registries should not modify the usual care that physicians provide to their patients, there should be little or no conflict between their role of physician and that of participant in the registry. (See Chapter 7.) In addition, patients may see participation in the registry as an opportunity to increase their communication with their clinician. Another incentive for many patients is the feeling that they are contributing to the knowledge base of sometimes poorly understood and undertreated conditions.

Recruitment of patients presents different challenges, depending on the nature of the condition being studied. In general, patient recruitment plans should address the following questions:

- Does the plan understand the needs and interests of potential participants?
- Does the plan address patient recruitment issues and procedural challenges, including informed consent and explanation of risks?
- What are the patient retention goals? What is a reasonable followup period? What is a reasonable followup rate? When does reduced retention compromise validity?
- What, if any, patient incentives are offered, including different types of incentives and the ethical, legal, or study validity issues to be considered with patient incentives?
- What are the costs of patient recruitment and retention?

Table 10–3 summarizes the key factors for patient recruitment and lists several specific methods that might be used for recruiting patients, grouped by the basic categories of patients at the time of recruitment.

Table 10–3 Patient recruitment

Keys to patient recruitment | - Recruit through a physician who is caring for the patient.; - Communicate to the patient that registry participation may help to improve care for all future patients with the target condition.; - Write all patient materials (brochures, consent forms) in a manner that is easily understandable by the lay public.; - Keep the survey forms short and simple.; - Provide incentives. These can be nonmonetary, such as functions relevant to the patient's care (reports) or community (newsletters, portals). In some cases, monetary incentives can be offered if approved by the institutional review board.; - Actively plan how to include minorities or other populations of interest.
Methods of patient recruitment | - Noninstitutionalized residents of the general U.S. population:; – Recruit via letter survey, telephone, or email.; – Recruit during well-patient visits to outpatient clinics.; – Recruit via patient advocacy and support groups, health information Web sites, etc.; – Register in the Registry of Patient Registries (RoPR) to increase awareness.; - Outpatients attending the clinic of a physician who is participating in the registry:; – Recruit through the patient's physician.; – Recruit via brochures placed in physician's office.; - Hospital inpatients who are hospitalized for treatment of a condition that is the subject of the registry:; – Recruit through the patient's physician.; – Recruit through hospitalists or consultant specialists.; – Recruit through a hospital research coordinator.; - Residents of nursing homes and similar long-term care facilities:; – Establish a relationship with the nursing home and staff.

### 2.5 Partnerships To Facilitate Recruitment

Many agencies/organizations can assist in the recruitment of physicians and patients. These partners may have access to patients or their families and physicians who treat the condition, and they may lend credibility to the effort. These agencies/organizations include—

- Government agencies
- Physician professional associations or State medical associations
- Certifying boards (e.g., American Board of Neurological Surgeons)
- Patient advocacy groups (e.g., Muscular Dystrophy Association)
- Nonprofit foundations (e.g., Robert Wood Johnson Foundation)
- Industry (e.g., pharmaceutical companies)
- HMOs and other third-party insurance providers

### 2.6 Procedural Considerations Related To Recruitment

When developing a recruitment plan for a registry, consideration should be given to the procedural concerns that may be factored into potential participants' decisions. These concerns include the roles and responsibilities of each party, the need and process for obtaining institutional review board (IRB) approval, and the management of patient and provider confidentiality.

The contract between registry sites and the sponsor or coordinating center should clearly state the roles and responsibilities of the participants, the registry-coordinating center, and the sponsor. If remuneration is being offered, the data-entry requirements that need to be fulfilled before payments are made should be stated. It is often helpful to explain to sites the concept of fair market value. Where the Health Insurance Portability and Accountability Act (HIPAA) applies, consideration should also be given to new requirements in the HIPAA Privacy Rule that prohibit a covered entity from disclosing protected health information in exchange for remuneration from the recipient of that information without the individual's authorization, subject to a number of exceptions (see 45 CFR 164.502(a)(5)(ii)). There is no specific formula (such as whether to separate startup payments from per-patient payments), but total remuneration must reflect work effort for the specific registry. Some individual factors, ranging from location to specialty, may have a bearing on fair market value. It is also important to spell out which entity will have ownership of the data and how the data will be used.

The contract should clearly explain the registry policy regarding any necessary approvals. If review by an IRB is required, generic templates can be offered to participants to assist them in obtaining ethical and IRB approval. Because the costs of obtaining IRB approval are often substantial, it is essential that the contract with the participants clearly indicate which party is responsible for bearing this cost. If the registry developer believes that IRB or privacy board review or approval is not required or may be waived, then a clear rationale should be provided to the prospective participants (see Case Example 57). As discussed in Chapter 7, the research purpose of the registry, the type of entity that creates and maintains it, whether the Common Rule applies to the particular site, and the extent to which the data are individually identifiable largely determine which regulatory requirements apply. For example, for registries limited to certain purposes, such as quality improvement, institutions may not need IRB approval.3

Patient privacy and participant confidentiality should be addressed in the registry materials. Methods of ensuring patient privacy need to be clearly elucidated in all registry-related documentation. Case report forms and patient logs must be designed to minimize patient identification (such as by transmitting limited data sets rather than more identifiable information, if such information is not required to meet a registry objective).

The intended management of the confidentiality of participating providers should be explained in the contract. Mechanisms for protecting provider confidentiality, including Certificates of Confidentiality and Patient Safety Organizations, are discussed in Chapters 7 and 9. If third-party or public reporting is an intended component of the registry, the specific data to be shared, the level of the disclosure (e.g., hospital and/or physician level), and the permitted receiving entities need to be articulated and the control mechanisms explained.

## 3 Retention

### 3.1 Providers

Once hospitals and physicians are recruited to participate in a registry, retaining them becomes a key to success. All of the factors identified as important for recruitment are important for retention as well. A critical factor in retention is delivery on promises made during recruitment (e.g., that the burden of participation is low). By carefully pilot testing all aspects of the registry prior to full recruitment, there is less likelihood that problems will arise that threaten the registry's reputation. Registries with an advisory board or steering committee can use this resource to help with retention. A visible and independent advisory board adds transparency and credibility, sets appropriate expectations among its peers on what to expect from a registry (e.g., compared with a clinical trial), ensures that the burden of the registry is minimized (or at least never outweighs its value to participants), and maintains the relevance and currency of the registry for the investigators. Ideally, advisory board members serve as ambassadors for the program. The level of credibility, engagement, practicality, and enthusiasm of the advisory board can significantly affect provider recruitment and retention. For example, an advisory board whose clinical members are not themselves participating in the registry will have greater difficulty than a board with participating members in addressing the concerns of participating practices that invariably arise over the course of the registry. Including patients or patient advocacy organization representatives on the advisory board also can support patient retention efforts. These representatives can provide feedback to the board on patient issues or concerns about the registry, and they can facilitate communication about the registry's purpose and value to their peers or members.

Throughout the registry's duration, communication from the data coordinating center and the advisors, as well as community building, are important for strong retention. Early and continued engagement of the site champions or principal investigators is very important. Some registries use periodic face-to-face meetings of principal investigators from participating sites. When this approach is not economically feasible, well-planned online meetings can serve the same purpose.

Visibility of the registry at relevant national meetings can help maintain clinician awareness and sense of community, and regular demonstration of its value through presentations and publications reinforces the credibility of the registry to its participants. As the data set grows, so too does the value of the registry for all participants, and regular updates on the registry growth can be important. Finally, enhancing site value through nonfinancial rewards can be particularly useful in retention, and the registry should continually seek to bring value to the participants in creative and useful ways.

Participation retention tools include—

- Web sites
- Newsletters
- Telephone helplines
- Instruction manuals
- Training meetings
- Site audit/retraining visits
- Customer satisfaction/opinion surveys
- Regular data reports to stakeholders
- Presentations at conferences
- Regular reports to registry participants on registry growth and publications
- Ability of participating physicians to publish based on registry data (depending on the data access policy of the registry)

### 3.2 Patients

Retaining patients as active participants in registries with longitudinal followup is an ongoing challenge. Many factors need to be considered in developing a retention plan, including how long the patient is likely to return to the enrolling site. Patients enrolled in a primary care practice for a chronic illness can likely be followed in that practice for some time, although there should be a plan for how the registry will (or will not) address the issue of patients who transfer to unenrolled practices. Different solutions are needed for patients enrolled in a hospital at discharge or through a specialist who does not follow the patient long term. Several options exist. They include enlisting site staff to reach out to patients beyond their standard interactions,4 following patients directly through a central patient management center,5 and linking to other data sources (e.g., National Death Index, claims data) to obtain key long-term outcomes data on patients who are lost to followup. Retention plans, including contingencies, should be considered during registry planning, as they may require additional permissions (e.g., for direct contact) or data elements (e.g., for linkage). Maintaining ethical incentives for patient participation (ranging from newsletters to payments) is important for some registries (e.g., those that collect patient-reported outcomes data). Beyond planning for how to retain patients in a registry, it is important to track actual versus expected followup rates over time and to respond if rates are not meeting expectations. The resources available for patient retention efforts should also be clear. Followup rates can often be improved with more efforts, such as more attempts to contact the patient, but these efforts add costs and, at some level, will yield diminishing returns.

## 4 Pitfalls in Recruitment and Retention

Pitfalls abound in recruitment and retention. The most important of these pitfalls is the risk of selection bias. Targeting hospital-based or academic physicians to the exclusion of community-based physicians is tempting because the former are often more accessible and are frequently more open to involvement in, and more experienced in, research projects. Similarly, targeting high-volume practices or centers will improve efficiency of patient enrollment, but may not yield an adequately representative sample of care practices. If an advisory board or committee is used to help design the registry and aid in recruitment, there may be a tendency for advisors to recruit known colleagues or to target disease experts, when a wider range of participants may be necessary to provide the appropriate data to meet the research goals. Including representatives from the range of anticipated site types on the advisory board can be helpful.

Even with an appropriate mix of physician participants in a registry, biases in patient recruitment may still occur. For example, older and more seriously ill patients may be excluded because of challenges in enrollment and followup or poorer outcomes. From the outset, physicians involved in recruitment efforts need to be aware of the potential for bias, and they must understand the importance of adhering to well-delineated inclusion and exclusion criteria. They must also adhere to the registry's enrollment strategy, which is typically designed to reduce this bias (e.g., consecutive or randomized enrollment). In addition, overly demanding data collection requirements can affect retention. The schedule should be designed to obtain relevant data in a timely fashion without overtaxing the resources of patients and providers. It is also important to consider approaches that will distinguish patients who are lost to followup from those who have missing data for other reasons (such as a patient who missed a visit but is still in the registry).

Another major pitfall is confusing terminology. This can be a major problem when the registry is international. When designing training materials, instruction manuals, and questionnaires, it is critical that the language and terminology be clear and concise. Materials that are translated into other languages must undergo strict quality assurance measures to ensure that terms are translated properly (e.g., back translation).

## 5 International Considerations

While many general principles are similar for participant enrollment and retention in other parts of the world, there are many different customs or regulations regarding contract language, requirements for ethics committee or other submissions, informed consent, and allowable approaches to patient retention. Registries that extend to other countries should consult national and local regulations in those countries.

## Case Examples for Chapter 10

Case Example 20 Building value as a means to recruit hospitals

Description | Get With The Guidelines^®^ is the flagship program for in-hospital quality improvement of the American Heart Association (AHA) and American Stroke Association (ASA). The program uses the experience of the AHA and ASA to ensure that the care that hospitals provide for heart failure, stroke, and resuscitation is aligned with the latest evidence-based guidelines.
Sponsor | American Heart Association and American Stroke Association
Year Started | 2000
Year Ended | Ongoing
No. of Sites | 3,150
No. of Patients | 3,174,462 patients and 4,253, 461 patient records in Get With The Guidelines-Inpatient (Stroke, HF, and Resuscitation)

#### Challenge

Recruiting hospitals for registries or quality improvement (QI) programs can be arduous. Human and financial capital is constrained. Accreditation and reimbursement programs, such as those of The Joint Commission (formerly the Joint Commission on Accreditation of Healthcare Organizations, or JCAHO) and Centers for Medicare & Medicaid Services (CMS), contend for the same valuable human and financial capital. As a result, in the absence of specific benefits, many hospitals defer the data collection and report utilization required for successful QI execution.

Like most registries and QI programs, the sponsor's program faced barriers to data entry. Unlike other registries, Get With The Guidelines offered no reimbursements for data entry and entered a market characterized by significant competition. The registry team wanted to motivate resource-strapped hospitals to consistently and proactively enter data and analyze improvement.

#### Proposed Solution

The registry team began by listening to the hospitals through in-depth interviews designed to understand the motivations and deterrents underlying behavior. Interviews were conducted with hospital decisionmakers at all levels (nurses, QI professionals, administrators/chief executive officers, and physicians).

Based on the research findings, the team developed strategies that differentiated and built value for the program. Some of the more noteworthy strategies included the following:

- Systems were designed to allow data transmission from and to Joint Commission and CMS vendors, enabling hospitals to reduce the burden of duplicate data entry while still participating in other programs.
- A new tagline, Turning Guidelines into LifelinesSM, linked the brand's value proposition to the brand name and logo. Key messages for each target audience were included in marketing communications.
- A newly designed national recognition program motivated participation and advancement, and received the attention of hospital decisionmakers.
- Return-on-investment studies for the program demonstrated the value of participation.

Product innovations/enhancements created additional incentives to participate. Immediate point-of-care flags highlighted variances from guidelines. Benchmarking filters/reports empowered decisionmakers to benchmark performance with national averages and data from similar institutions. Customizable notes explaining diseases, tests, and medications can be sent to both the referring physician and the patient.

#### Results

By providing a mix of innovative nonfinancial incentives, the program increased both enrollment and advancement by about one-third in 12 months. Currently, 3,150 hospitals participate in the program. The database includes 4,253,461 patient records and is considered by many to be the most robust database for heart failure, stroke, and resuscitation. In 2004, the program received the Innovation in Prevention Award from the Department of Health and Human Services.

#### Key Point

Nonfinancial incentives that meet the needs of decisionmakers can assist in recruitment of sites. When creating such incentives, consider both tangible and nontangible benefits.

#### For More Information

http://www.heart.org/quality

Case Example 21 Using registry tools to recruit sites

Description | The objective of the OPTIMIZE-HF (Organized Program to Initiate Lifesaving Treatment in Hospitalized Patients with Heart Failure) registry was to improve quality of care and promote evidence-based therapies in heart failure. The registry provided a comprehensive process-of-care improvement program and gathered data that allowed hospitals to track their improvement over time.
Sponsor | GlaxoSmithKline
Year Started | 2003
Year Ended | 2005
No. of Sites | 270
No. of Patients | More than 50,000

#### Challenge

The registry was designed to help hospitals improve care for patients hospitalized with heart failure. The objective was to accelerate the adoption of evidence-based guidelines and increase the use of the guideline-recommended therapies, thereby improving both short-term and long-term clinical outcomes for heart failure patients.

#### Proposed Solution

To increase compliance with guidelines, the registry team promoted the implementation of a process-of-care improvement component and the use of comprehensive patient education materials. They combined these materials into a hospital toolkit, which included evidence-based practice algorithms, critical pathways, standardized orders, discharge checklists, pocket cards, and chart stickers. The toolkit also included algorithms and dosing guides for the guideline-recommended therapies and a comprehensive set of patient education materials. The team engaged the steering committee in designing the toolkit to ensure that the materials reflected both the guideline-recommended interventions and the practical aspects of hospital processes.

In addition to the toolkit, the registry offered point-of-care tools, such as referral notes and patient letters, that could be customized for each patient based on data entered into the registry. The registry also included real-time performance reports that hospitals could use to assess their improvement on a set of standardized measures based on the guidelines.

#### Results

The hospital toolkit was a key component of the registry's marketing campaign. Hospitals could view the toolkit at recruitment meetings, but they did not receive their own copy until they joined the program. The toolkit gained credibility among hospitals because its creators included some of the most prominent members of the heart failure research and treatment community. Hospitals also actively used the reports to track their improvement over time and identify areas for additional work. Overall, the registry recruited 270 hospitals and met its patient accrual goal six months ahead of schedule.

#### Key Point

Nonfinancial incentives, such as patient education materials, toolkits, and reports, can encourage sites to join a registry. Incentives that also add value for the site by improving their processes or providing materials that they use frequently can aid retention.

#### For More Information

Fonarow GG, Abraham WT, Albert NM, et al. Organized Program to Initiate Lifesaving Treatment in Hospitalized Patients with Heart Failure (OPTIMIZE-HF): rationale and design. Am Heart J. 2004;148(1):43-51. [pmid: 15215791]. .

Gheorghiade M, She L, Abraham WT, et al. Systolic blood pressure at admission, clinical characteristics, and outcomes in patients hospitalized with acute heart failure. JAMA. 2006;296:2217-26. [pmid: 17090768]. .

Fonarow GC, Abraham WT, Albert NM, et al. Association between performance measures and clinical outcomes for patients hospitalized with heart failure. JAMA. 2007;297:61-70. [pmid: 17200476]. .

Case Example 22 Using a scientific advisory board to support investigator research projects

Description | The National LymphoCare Study is a large, prospective, disease-based registry in the area of follicular lymphoma in the United States. There are a number of open clinical questions about follicular lymphoma treatment, including whether anthracyclines should be used early in the course of disease, and whether there is a group of patients for whom observation (as opposed to active treatment) is the best choice, given the indolent nature of the disease. The registry follows patients for up to 10 years, and specific outcomes of interest include overall response rate, progression-free survival, time to subsequent therapy, and overall survival for common frontline and subsequent therapeutic strategies.
Sponsor | Genentech, Inc., and Biogen Idec, Inc.
Year Started | 2004
Year Ended | Ongoing
No. of Sites | 250 community and academic sites
No. of Patients | Over 2,700

#### Challenge

The National LymphoCare Study includes a large number of community-based sites in addition to many academic sites. Many of the principal investigators at the community-based sites are interested in using the registry data to answer clinical questions, but they do not have sufficient research experience to design a research question, conduct data analysis, and share the results with the scientific community. One aim of the registry sponsors and scientific advisory board (SAB) is to facilitate research among the community investigators, both to increase interest in the registry and to increase the scope of research questions addressed using registry data.

#### Proposed Solution

The registry sponsors and the SAB developed a plan to allow investigators at enrolling sites to propose a question of interest; work with an SAB member, clinical scientists, epidemiologists, and biostatisticians to develop an analysis plan to answer the question; and present findings at scientific meetings. The plan was implemented in 2007, when the registry issued a call for research proposals to all participating investigators. The proposal outlined the types of data that were available at that point (e.g., descriptive data on demographics, initial treatments, etc.). Several community-based investigators sent in proposals, which the SAB then reviewed. The SAB selected the proposals that it felt were most appropriate for the available data and that answered the most valuable questions from a clinical standpoint.

The community investigator for each selected proposal was then paired with a member of the SAB to further develop the research question. This process included conference calls and emails to refine the question and the high-level analytic plan. Once the plan was ready, the investigator and the SAB member submitted the proposal and analytic plan to the registry sponsor. The sponsor provided support for analytic design and biostatistics. The investigator, in consultation with the SAB member, developed an abstract based on the results. Abstracts were reviewed by the full SAB before being submitted for presentation.

#### Results

In 2007, a community-based investigator project developed through this process was accepted for abstract presentation at the annual American Society of Hematology (ASH) meeting. In 2009, a community-based investigator and a fellow at an academic institution developed abstracts that have been submitted for presentation at the annual ASH meeting.

With outcomes data now available in the registry, registry sponsors plan to issue calls for proposals twice per year, with the goal of generating abstracts for the annual ASH meeting and the annual American Society of Clinical Oncology meeting. To date, the research program has been well received by community-based investigators, who have the opportunity to author their own research projects with mentoring from an experienced advisor. The SAB has also been enthusiastic about working with community-based physicians on research methodology and adding to the scientific knowledge about this disease.

#### Key Point

Community-based investigators who participate in a registry may be interested in pursuing research opportunities but may not have all of the necessary resources or expertise. By utilizing an engaged advisory board, a registry can provide investigators with research opportunities, resulting in more publications and presentations based on registry data, and potentially more engaged investigators.

#### For More Information

Friedberg JW, Taylor MD, Cerhan JR, et al. Follicular lymphoma in the United States: first report of the National LymphoCare Study. J Clin Oncol. 2009;27:1202-8. [pmid: 19204203]. .

Friedberg JW, Wong EK, Taylor MD, et al. Characteristics of patients with stage I follicular lymphoma (FL) selected for watchful waiting (WW) in the US: report from the National LymphoCare Study (NLCS). American Society of Hematology. 2007. Abstract 3315. .

Link BK, Taylor MD, Brooks JM, et al. Correlates of treatment intensity for initial management of follicular lymphoma (FL) in the United States: report from the National LymphoCare Study (NLCS). American Society of Hematology. 2007. Abstract 2612. .

Matasar MJ, Saxena R, Wong EK, et al. Practice patterns in the diagnosis of follicular lymphoma (FL): report from the National LymphoCare Study (NLCS). American Society of Hematology. 2007. Abstract 2613. .

Nabhan C, Morawa E, Bitran JD, et al. Patterns of care in follicular lymphoma (FL): are minorities being treated differently? Report from the National LymphoCare Study (NLCS). American Society of Hematology. 2007. Abstract 367. .

Case Example 23 Identifying and addressing recruitment and retention barriers in an ongoing registry

Description | Tracking Operations and Outcomes for Plastic Surgeons (TOPS) is a national registry of plastic surgery procedures and outcomes used to track and assess 30-day post-operative outcomes.
Sponsor | American Society of Plastic Surgeons (ASPS)
Year Started | 2002
Year Ended | Ongoing
No. of Sites | 425–450 annually
No. of Patients | 611,682 complete cases and 1,094,268 plastic surgery procedures

#### Challenge

TOPS was initially launched in 2002 as a program designed to provide ASPS member plastic surgeons with a mechanism to track demographic, procedural, and outcomes information to help physicians benchmark and evaluate their practice. The registry uses an electronic data capture interface to collect common demographic, risk factor, procedural, and 30-day outcome data elements, which allow registry users to evaluate outcomes based on patient comorbidities and risk factors and track the rate and type of surgical incidences that could occur postoperatively. The registry has become an integral part of ASPS efforts and is used in many of the society's key initiatives, including developing evidence-based practice parameters, monitoring clinical outcomes and emerging trends, supporting research and educational programs, and compilation of the National Clearinghouse Plastic Surgery Statistics.

A majority of the registry participants contribute data annually. However, due to the voluntary nature of the registry, the registry also includes “one-time” users. Since 2002, more than 1,600 ASPS members have participated in the registry at any given time, leaving a large number of ASPS members choosing not to participate at all, and some ASPS members who choose to stop participating or participate sporadically. In order to encourage broad and continued participation from society members, the society sought to fully understand the needs of its members and develop strategies to retain and recruit participants for the ongoing registry.

#### Proposed Solution

To improve the program's value to member surgeons, the ASPS regularly evaluates member and organization needs to make upgrades and improve the registry. The ASPS surveyed its society membership in 2008 and 2012 to better understand reasons for both continued participation and lack of use. Survey results indicated that earning credits towards continuing medical education, society-awarded patient safety credits, and contributing to important scientific endeavors were strong reasons for continued participation. In addition, individual physician practices perceived value in the registry's ability to track patients' outcomes over time and benchmark practice data against other practices in the registry. Many nonusers reported their willingness to participate if the registry supported integration with their practice's electronic medical records (EMR) system. Other reasons for nonparticipation included perceived limited usefulness of data collection to physician practice and site-based barriers such as insufficient resources.

#### Results

Based on the survey feedback, the ASPS elected to increase functionality to make the registry more relevant to members. Updates to the registry were made in 2007, 2009, and 2011, and included the introduction of credentialing reports, enhanced benchmarking reports, collection of patient-reported outcomes (PRO), and enhanced data entry and querying reporting functions. The credentialing reports allow registry users to review their individual patient data by facility, with options to filter by medical record number, name, date range, procedure type, and outcome. The existing benchmarking reports were enhanced, allowing users to benchmark their individual data against aggregate registry data; customizations were also added, allowing users to filter by time period and procedure type. The registry also began electronically collecting PRO data from breast augmentation and reconstruction patients using the BREAST-Q^©^ questionnaire; the PRO data supports metrics for documenting clinical performance appraisal and improvement based on the patients' responses. Users can develop PRO reports and create dynamic customized graphs and charts in order to assess patient satisfaction across PRO domains, such as satisfaction with outcome, psychosocial well-being, and satisfaction with care. In response to member requests, the upgrades also included new functionality to support data transfer from EMR and practice management programs to ease data entry burden on sites.

#### Key Point

Within an ongoing, voluntary registry, retaining and recruiting participants requires maintaining relevance to users. Surveys or other methods of collecting feedback from registry participants and potential participants can be useful tools for discovering recruitment or retention barriers and identifying potential improvements to maintain relevance.

#### For More Information

http://www.plasticsurgery.org/for-medical-professionals/surgeon-community/tops.html

## References for Chapter 10

1 Scios. Scios Announces ADHERE Heart Failure Registry Meets JCAHO Standards for Hospital Accreditation. http://www.prnewswire.com/news-releases/scios-announces-adhere-heart-failure-registry-meets-jcaho-standards-for-hospital-accreditation-77976192.html. August 15, 2012.
2 Centers for Medicare & Medicaid Services. Medicare Coverage Database. http://www.cms.gov/medicare-coverage-database/overview-and-quick-search.aspx?id=8. August 15, 2012.
3 Dokholyan RS, Muhlbaier LH, Falletta JM, et al. Regulatory and ethical considerations for linking clinical and administrative databases. Am Heart J. Jun. 2009;157(6):971-82. [pmid: 19464406].
4 Gheorghiade M, Abraham WT, Albert NM, et al. Systolic blood pressure at admission, clinical characteristics, and outcomes in patients hospitalized with acute heart failure. JAMA. Nov. 8. 2006;296(18):2217-26. [pmid: 17090768].
5 Spertus JA, Peterson E, Rumsfeld JS, et al. The Prospective Registry Evaluating Myocardial Infarction: Events and Recovery (PREMIER)--evaluating the impact of myocardial infarction on patient outcomes. Am Heart J. Mar. 2006;151(3):589-97. [pmid: 16504619].