# Case Example Contributors

The findings and conclusions in this document are those of the contributors and reviewers. The contributors and reviewers participated as individuals and not necessarily as representatives of their organizations. No statement in this document should be construed as an official position of any organization represented here.

1 Creating a Registry To Fulfill Multiple Purposes and Using a Publications Committee To Review Data Requests
- Edna Stoehr
- Michelle Bertagna Leavy, M.P.H.

2 Designing a Registry for a Health Technology Assessment
- Michelle Bertagna Leavy, M.P.H.
- Hannah Patrick

3 Developing Prospective Nested Studies in Existing Registries
- Joel M. Kremer, M.D.
- Pattra Mattox, S.M.
- Dimitrios Pappas, M.D., M.P.H.

4 Designing a Registry To Address Unique Patient Enrollment Challenges
- Karen Domino, M.D., M.P.H.
- Laura Khurana, M.P.H.
- Karen L. Posner, Ph.D.

5 Selecting Data Elements for a Registry
- Michelle Bertagna Leavy, M.P.H.
- R. Scott McKenzie, M.D.

6 Understanding the Needs and Goals of Registry Participants
- Michelle Bertagna Leavy, M.P.H.
- John Spertus, M.D., M.P.H., FACC, FAHA

7 Using Standardized Data Elements in a Registry
- Laura Khurana, M.P.H.
- Sheri Sanders, M.B.A., B.S.N., R.N.
- Wendy Schroeder, R.N., B.S.N., CCRC, CRCP, CHRC

8 Developing and Validating a Patient-Administered Questionnaire
- Michelle Bertagna Leavy, M.P.H.
- Grannum Sant, M.D., FRCS, FACS

9 Using Validated Measures To Collect Patient-Reported Outcomes
- Kathleen M. Fox, Ph.D., M.H.S.
- Susan Grandy, Ph.D., M.B.A.
- Michelle Bertagna Leavy, M.P.H.

10 Challenges in the Collection of PROs in a Longitudinal Registry
- Ethan Basch, M.D., M.Sc.
- Antonia V. Bennett, Ph.D.
- Pattra Mattox, S.M.

11 Collecting PRO Data in a Sensitive Patient Population
- Waguih William IsHak, M.D., FAPA
- Laura Khurana, M.P.H.

12 Using Claims Data Along With Patient-Reported Data To Identify Patients
- Vinicius Antao, M.D., M.Sc., Ph.D.
- D. Kevin Horton, Dr.P.H., M.S.P.H.
- Pattra Mattox, S.M.
- Oleg Muravov, M.D., Ph.D.

13 Obtaining a Waiver of Informed Consent
- Mark J. Fox
- Michelle Bertagna Leavy, M.P.H.

14 Issues With Obtaining Informed Consent
- Moira K. Kapral, M.D., M.Sc., FRCPC
- Janice A. Richards, R.N., B.A.
- Jack V. Tu, M.D., Ph.D.

15 Operationalizing Informed Consent for Children
- Catherine Birken, M.D., M.Sc., FRCPC
- Laura Khurana, M.P.H.
- Jonathon Maguire, M.D., M.Sc., FRCPC
- Magda Nunes de Melo, B.Sc.Pharm., M.Sc.
- Patricia Parkin, M.D., FRCPC

16 Using a Patient-Centered Study Design To Collect Informed Consent, Maximize Recruitment and Retention, and Provide Meaningful Clinical Data
- Christina Pavetto Bond, M.S., FACHE
- Patricia Franklin, M.D., M.B.A., M.P.H.
- Laura Khurana, M.P.H.

17 Handling Discovery Requests for Registry Data
- Mark J. Fox
- Laura Khurana, M.P.H.

18 Meeting the Confidentiality and Quality Improvement Needs of Providers Through a Patient Safety Organization
- Karen Domino, M.D., M.P.H.
- Laura Khurana, M.P.H.
- Karen L. Posner, Ph.D.
- Donald C. Tyler, M.D., M.B.A.

19 Protections Available to Registry Data From Institutional Review Boards and Academic Institutions
- Karen Domino, M.D., M.P.H.
- Michelle Bertagna Leavy, M.P.H.
- Karen L. Posner, Ph.D.

20 Building Value as a Means To Recruit Hospitals
- Sara Camp, R.N., M.S.N., A.C.N.P., CCRN-CSC
- Michelle Bertagna Leavy, M.P.H.

21 Using Registry Tools To Recruit Sites
- Michelle Bertagna Leavy, M.P.H.

22 Using a Scientific Advisory Board To Support Investigator Research Projects
- Michelle Bertagna Leavy, M.P.H.
- Michael D. Taylor, Pharm.D., Ph.D.

23 Identifying and Addressing Recruitment and Retention Barriers in an Ongoing Registry
- Katie Crotty, M.P.H., CCRP
- Keith M. Hume, M.A.
- Pattra Mattox, S.M.
- Christopher Simmons, B.S., B.A.

24 Developing a Performance-Linked Access System
- Michael Karukin, P.A., Ph.D.
- Michelle Bertagna Leavy, M.P.H.

25 Using Audits To Monitor Data Quality
- Jack L. Cronenwett, M.D.
- Michelle Bertagna Leavy, M.P.H.

26 Using Registry Data To Evaluate Outcomes by Practice
- Michelle Bertagna Leavy, M.P.H.
- Jeffrey Wagener, M.D.

27 Using Registry Data To Study Patterns of Use and Outcomes
- Marnie L. Boron, Pharm.D.
- Michelle Bertagna Leavy, M.P.H.

28 Determining When To Stop an Open-Ended Registry
- Jessica Albano, Ph.D., M.P.H.
- Ann Mallard, M.P.H.
- Pattra Mattox, S.M.

29 Challenges in Transitions and Changes in Data Collection
- Alexander Elbert, Ph.D.
- Emily A. Knapp
- Bruce C. Marshall, M.D.
- Pattra Mattox, S.M.
- Kristofer M. Petren

30 Transitioning From Startup to Ongoing Registry Funding With Public and Private Partners
- Ani John, B.S.N., M.P.H.
- Laura Khurana, M.P.H.
- Marc C. Levesque, M.D., Ph.D.

31 Modifying a Registry Due to Changes in Standards of Care
- Dawn Eng, R.N., B.S.N.
- Alexandra Gillmore, M.S.

32 Using System Integration Software To Capture Registry Data From Electronic Health Records
- Mark J. Fox
- Michelle Bertagna Leavy, M.P.H.
- Kristi R. Mitchell, M.P.H.

33 Creating a Registry Interface To Incorporate Data From Multiple Electronic Health Records
- Laura Khurana, M.P.H.
- Jen Moore

34 Technical and Security Issues in Creating a Health Information Exchange
- Jenifer Hughes, Med.I.T.
- Michelle Bertagna Leavy, M.P.H.

35 Developing a New Model for Gathering and Reporting Adverse Drug Events
- Daniel Levy, M.S.

36 Linking Registries at the International Level
- Laura Khurana, M.P.H.
- Luigi Naldi, M.D.

37 Linking a Procedure-Based Registry With Claims Data To Study Long-Term Outcomes
- Mark J. Fox
- Michelle Bertagna Leavy, M.P.H.

38 Linking Registry Data To Examine Long-Term Survival
- Richard Feltbower, Ph.D.
- Pattra Mattox, S.M.
- Patricia McKinney, Ph.D.
- Roger Parslow, Ph.D.
- Marlous Van Laar, M.Sc.

39 Linking Longitudinal Registry Data to Medicaid Analytical Extract Files
- Efe Eworuke, Ph.D.
- Pattra Mattox, S.M.
- Almut Winterstein, Ph.D.

40 Integrating Data From Multiple Sources With Patient ID Matching
- Noam H. Arzt, Ph.D.
- Michelle Bertagna Leavy, M.P.H.

41 Using Patient Identity Management Methods To Combine Health System Data
- Laura Khurana, M.P.H.
- Roshanthi Weerasinghe, M.P.H.

42 Combining De-Identified Data From Multiple Registries To Study Long-Term Outcomes in a Rare Disease
- Monika Brand
- Laura Khurana, M.P.H.
- Erwan Muros Le Rouzic, M.P.H.
- Daniel Rosenberg, Ph.D., M.P.H.
- Barbara Schwierin, Ph.D.

43 Understanding Baseline Characteristics of Combined Data Sets Prior to Analysis
- Maria Inacio, M.S.
- Laura Khurana, M.P.H.
- Gregory B. Maletis, M.D.
- Elizabeth Paxton, M.A.

44 Using a Registry To Assess Long-Term Product Safety
- Pattra Mattox, S.M.
- Deborah Symmons, M.D.

45 Using a Registry To Monitor Long-Term Product Safety
- Michelle Bertagna Leavy, M.P.H.
- Rachel Sobel, Dr.P.H.

46 Using Registries To Understand Rare Diseases
- Betsy Bogard, M.S.
- Catherine Koepper
- Nicole Robichaud
- John Yee, M.D., M.P.H.

47 Studying Rare Diseases in an Existing Registry Population
- Charles Barr, M.D., M.P.H.
- Laura Khurana, M.P.H.
- Barbara Lippe, M.D.
- Anne Morris, Ph.D.

48 Site Motivation and Retention in Rare Disease Registries
- Monika Brand
- Alexandra Gillmore, M.S.
- Erwan Muros Le Rouzic, M.P.H.
- Daniel Rosenberg, Ph.D., M.P.H.
- Barbara Schwierin, Ph.D.

49 Expanding an Ongoing Pregnancy Registry
- Jessica Albano, Ph.D., M.P.H.
- Deborah Covington, Dr.P.H.
- Laura Khurana, M.P.H.

50 Using a Pregnancy Registry To Detect Major Teratogenicity
- Marianne Cunnington
- Lianna Ishihara
- Pattra Mattox, S.M.

51 Implementing a Non-Mandated Pregnancy Registry
- Dawn Eng, R.N., B.S.N.
- Laura Khurana, M.P.H.

52 Using Proactive Awareness Activities To Recruit Patients for a Pregnancy Exposure Registry
- Michelle Bertagna Leavy, M.P.H.
- Susan Sinclair Roberts, Ph.D.

53 Using Recognition Measures To Develop a Data Set
- Kenneth A. LaBresh, M.D.
- Michelle Bertagna Leavy, M.P.H.
- Louise Morgan, M.S.N., CPHQ
- Lee H. Schwamm, M.D., FAHA

54 Managing Care and Quality Improvement for Chronic Diseases
- Carl Donisi
- Keith Mandel, M.D.
- Pattra Mattox, S.M.
- Randy Woodward

55 Use of Reporting Tools To Promote Quality Improvement
- Rebecca S. Brown
- Pam Kadlubek, M.P.H.
- Pattra Mattox, S.M.

56 Using Registries To Drive Quality Improvement in Chronic Conditions
- Pattra Mattox, S.M.
- Peter Schmidt, Ph.D.

57 Clarifying the Federal Regulatory Requirements for Quality Improvement Registries
- Anthony L. Asher, M.D., FACS
- Laura Khurana, M.P.H.
- Koryn Y. Rubin

58 Designing a Registry To Study the Effectiveness of a Device Training Program for Providers
- Sidney A. Cohen, M.D., Ph.D.
- Michelle Bertagna Leavy, M.P.H.

59 Identifying and Responding to Adverse Events Found in a Registry Database
- Michelle Bertagna Leavy, M.P.H.
- Rebecca Love, M.P.H., R.N.
- Elizabeth Paxton, M.A.

60 Receiving Data From Medical Imaging Devices
- Mythreyi B. Chatfield, Ph.D.
- Laura Khurana, M.P.H.

61 Combining Registry Data With EHR Data To Measure Real-World Outcomes of Implantable Devices
- Robert Greenlee, Ph.D., M.P.H.
- Nat Jackson, M.S.
- Laura Khurana, M.P.H.
- Frederick Masoudi, M.D., M.S.P.H.

62 Developing a Public-Private Partnership for Comparative Effectiveness Research
- Elise Berliner, Ph.D.
- Flora Lum, M.D.
- Pattra Mattox, S.M.

63 Leveraging a Public-Private Partnership for a Post-Marketing Commitment
- Laura Khurana, M.P.H.
- Prof Dr Stefan Kölker
- Samantha Parker
- Marshall Summar, M.D.

64 Public-Private Partnerships for Rare Diseases
- Diane J. Aschman, M.S.
- Laura Khurana, M.P.H.
- Barbara Konkle, M.D.