# Linking Clinical Registry Data With Insurance Claims Files

A research project is being designed to compare the effectiveness for treating diabetes of one class of medication, or one specific generic medication within the class, to another. The results should provide scientific evidence for patients, physicians, and policymakers to use to make decisions about the use of these drugs.

Registry developer A will collect limited data sets of information on patients discharged with a diagnosis of diabetes from hospitals in three States. These limited data sets do not include patient names or direct identifiers, and so are not considered individually identifiable health information under the Health Insurance Portability and Accountability Act (HIPAA) Privacy Rule. The registry developer has institutional review board approval to use the data for research purposes. The hospitals will provide the data sets to group B under a data use agreement that complies with the HIPAA Privacy Rule.

Group B intends to perform probabilistic matching of the registry data to a health insurance claims database to determine diabetes treatment outcomes. Registry developer A and research group B have entered into a formal collaboration for this research project.

The health insurance database will be derived from the claims data of multiple health plans operating in the same three States. The insurers' original data sets include direct beneficiary identifiers and constitute protected health information under the HIPAA Privacy Rule. Because the registry contains only limited data sets, the claims data collected in the insurance database will have to be linked to the registry data using probabilistic matching techniques.

Consequently, the research project will use only a limited data set of health insurance claims data to create the link with the registry data. The health insurance companies will provide the limited data sets of claims information to group B under data use agreements that comply with the HIPAA Privacy Rule.

The common data elements for the insurance database and the registry that will be used for linkage are date of birth, gender, race, hospital ID, State of hospital, date of admission, date of discharge, date of death (if the patient died), ICD-9 (International Classification of Diseases, 9th Revision) code for primary diagnosis for the index hospitalization, primary procedure code for the index hospitalization, and ZIP Code for the patient's address.

In order to protect the identity of the hospitals, the researchers were asked to sign a confidentiality agreement that specifically defined the registry operator's proprietary information. Such proprietary information included the names or other identifiers of hospitals or other health care facilities participating in the registry. The researchers were precluded from using the names or other distinguishing characteristics of the hospitals in any public document, including publications or marketing materials. The confidentiality agreement did allow the researchers to retain an identifier number for each hospital, as long as that number identified only generic characteristics and excluded any information about the hospital that would enable anyone to identify the specific hospital. For example, the researchers could not retain information that classified a particular hospital with a number that identified it as an academic teaching hospital based in a particular State with a certain number of beds, since in many instances the identity of the hospital could be derived from such information. Due to the potential contractual liability that may arise, the possibility of identifying participating hospitals is a critical issue.