# Contributor and Reviewer Affiliations

The findings and conclusions in this document are those of the contributors and reviewers. The contributors and reviewers participated as individuals and not necessarily as representatives of their organizations. No statement in this document should be construed as an official position of any organization represented here.

- Amy P. Abernethy, M.D.
  Director, Center for Learning Health Care
  Director, Duke Cancer Care Research Program
  Associate Professor of Medicine, Duke University School of Medicine
  Associate Professor of Nursing, Duke University School of Nursing
  Durham, NC
- Susan Adams, J.D.
  Director, Committee for the Protection of Human
  Subjects
  Dartmouth College
  Hanover, NH
- Jessica Albano, Ph.D., M.P.H.
  Senior Director, Epidemiology, Post Approval & Strategic Services
  INC Research
  Raleigh, NC
- Fred Anderson, Ph.D.
  Research Professor of Surgery
  Director, Center for Outcomes Research
  University of Massachusetts Medical School
  Worcester, MA
- Vinicius Antao, M.D., M.Sc., Ph.D.
  Registries Team Lead
  Agency for Toxic Substances & Disease Registry/Centers for Disease Control and Prevention
  Atlanta, GA
- Paul S. Appelbaum, M.D.
  Elizabeth K. Dollard Professor of Psychiatry, Medicine & Law
  Director, Division of Law, Ethics, and Psychiatry
  Department of Psychiatry, Columbia University
  New York, NY
- Noam H. Arzt, Ph.D.
  President
  HLN Consulting, LLC
  Palm Desert, CA
- Diane J. Aschman, M.S.
  President and CEO
  American Thrombosis and Hemostasis Network
  Riverwoods, IL
- Anthony L. Asher, M.D., FACS
  Co-Medical Director, Neuroscience Institute, Carolinas Healthcare System
  Director, National Neurosurgery Quality and Outcomes Database
  Carolina Neurosurgery & Spine Associates
  Charlotte, NC
- Steven J. Atlas, M.D., M.P.H.
  Assistant Professor of Medicine
  Harvard Medical School
  Associate Physician, General Medicine Division
  Massachusetts General Hospital
  Boston, MA
- Landen Bain
  Liaison to Healthcare
  Clinical Data Interchange Standards Consortium
  Winston Salem, NC
- Charles Barr, M.D., M.P.H.
  Group Medical Director and Head of Patient Registries
  US Medical Affairs
  Genentech, Inc.
  South San Francisco, CA
- Ethan Basch, M.D., M.Sc.
  Associate Professor of Medicine and Public Health
  University of North Carolina
  Chapel Hill, NC
- Antonia V. Bennett, Ph.D.
  Assistant Professor of Public Health
  University of North Carolina
  Chapel Hill, NC
- Jessica Berg, J.D., M.P.H.
  Professor of Law, Bioethics & Public Health
  Case Western Reserve University School of Law and School of Medicine
  Cleveland, OH
- Marc L. Berger, M.D.
  Vice President, Real World Data and Analytics
  Pfizer
  New York, NY
- Elise Berliner, Ph.D.
  Director, Technology Assessment Program
  Center for Outcomes and Evidence
  Agency for Healthcare Research and Quality
  Rockville, MD
- Maya A. Bernstein, J.D.
  Privacy Advocate
  U.S. Department of Health and Human Services
  Washington, DC
- Stephen W. Bernstein, J.D.
  Head, Health Industry Practice Group
  McDermott Will & Emery, LLP
  Boston, MA
- Catherine Birken, M.D., M.Sc., FRCPC
  Staff Pediatrician and Associate Scientist
  University of Toronto
  Department of Pediatrics
  The Hospital for Sick Children
  Toronto, Canada
- Stella Blackburn, M.B., B.S., M.Sc., FRCP (Edin), FISPE
  EMA Risk Management Development and Scientific Lead
  European Medicines Agency
  London, United Kingdom
- Marcella Blackledge, B.A.
  CF Registry Coordinator
  Research Data Specialist II
  Seattle Children's Research Institute
  Seattle Children's Hospital
  Seattle, WA
- Kathleen Blake, M.D., M.P.H.
  Vice President, Physician Consortium for Performance Improvement
  American Medical Association
  Chicago, IL
- Betsy Bogard, M.S.
  Associate Director, Program Management
  Genzyme, a Sanofi company
  Cambridge, MA
- Christina Pavetto Bond, M.S., FACHE
  National Operations Director
  FORCE TJR
  Worcester, MA
- Marnie L. Boron, Pharm.D.
  Director, Scientific Communications
  MedImmune
  Gaithersburg, MD
- Jaclyn L. F. Bosco, Ph.D., M.P.H.
  Epidemiologist
  Real-World & Late Phase Research
  Quintiles
  Cambridge, MA
- Brian D. Bradbury, M.A., D.Sc.
  Director, Center for Observational Research
  Amgen, Inc.
  Adjunct Assistant Professor, Epidemiology
  UCLA Fielding School of Public Health
  Los Angeles, CA
- Monika Brand
  Associate Director, Observational Studies
  Actelion Pharmaceuticals Ltd
  Allschwil, Switzerland
- Ralph G. Brindis, M.D., M.P.H., MACC, FSCAI
  Clinical Professor of Medicine
  Department of Medicine & the Philip R. Lee Institute for Health Policy Studies
  University of California, San Francisco
  Senior Medical Officer, External Affairs - ACC National Cardiovascular Registry
  San Francisco, CA
- Jeanette M. Broering, R.N., Ph.D., M.P.H.
  Director, Data Operations
  Urology Clinical and Translational Science
  Department of Urology
  University of California San Francisco
  San Francisco, CA
- Jeffrey Brown, Ph.D.
  Research Director, Therapeutics Research and Infectious Disease Epidemiology Program
  Lecturer, Department of Population Medicine
  Harvard Pilgrim Health Care Institute/Harvard Medical School
  Boston, MA
- Rebecca S. Brown
  Quality Measures Coordinator, Quality and Guidelines
  American Society of Clinical Oncology
  Alexandria, VA
- Laura D. Buccini, Dr.P.H., M.P.H.
  Associate Staff, Digestive Disease Institute and Transplant Center
  The Cleveland Clinic
  Cleveland, OH
- Sara Camp, R.N., M.S.N., A.C.N.P., CCRN-CSC
  Director, Quality Marketing and Research
  American Heart Association
  Dallas, TX
- Daniel Caños
  Epidemiologist, Division of Epidemiology
  Office of Surveillance and Biometrics
  Center for Devices and Radiological Health
  Food and Drug Administration
  Silver Spring, MD
- Christina Chambers, Ph.D., M.P.H.
  Professor of Pediatrics
  Director, Organization of Teratology Information Specialists Collaborative Research Center
  University of California San Diego School of Medicine
  La Jolla, CA
- Mythreyi B. Chatfield, Ph.D.
  Director, Data Registries
  American College of Radiology
  Reston, VA
- Sidney A. Cohen, M.D., Ph.D.
  Formerly Vice President, Medical Affairs
  Cordis Corporation and Conor Medsystems
  Menlo Park, CA
- J. Alexander Cole, D.Sc., M.P.H.
  Director, Epidemiology
  Alexion Pharmaceuticals
  Cambridge, MA
- Deborah Covington, Dr.P.H.
  Global Head, Observational Studies and Pregnancy Registries
  PPD
  Wilmington, NC
- Janet D. Cragan, M.D., M.P.H.
  National Center on Birth Defects and Developmental Disabilities
  Centers for Disease Control and Prevention
  Atlanta, GA
- Jack L. Cronenwett, M.D.
  Professor of Surgery
  Dartmouth-Hitchcock Medical Center
  Medical Director
  Society for Vascular Surgery Patient Safety Organization
  Lebanon, NH
- Katie Crotty, M.P.H., CCRP
  Manager, Research and Scientific Affairs
  American Society of Plastic Surgeons
  Arlington Heights, IL
- Jay Crowley
  Senior Advisor for Patient Safety
  Center for Devices and Radiological Health
  Food and Drug Administration
  Silver Spring, MD
- Theresa Cullen, M.D., M.S.
  Chief Medical Informatics Officer
  Director, Health Informatics
  Veterans Health Administration
  Washington, DC
- Marianne Cunnington
  Formerly Manager, Worldwide Epidemiology
  GlaxoSmithKline
  Essex, United Kingdom
- David C. Dale, M.D.
  Professor of Medicine
  University of Washington School of Medicine
  Attending Physician, University of Washington Medical Center
  Seattle, WA
- Leonard D'Avolio, Ph.D.
  Director of Biomedical Informatics
  Massachusetts Veterans Epidemiology Research and Information Center
  Faculty, Harvard Medical School
  Boston, MA
- Joseph A.C. Delaney, Ph.D.
  Research Assistant Professor, Epidemiology
  University of Washington School of Public Health
  Seattle, WA
- Andy DeMayo, J.D.
  Senior Corporate Counsel
  Real-World & Late Phase Research
  Quintiles
  Cambridge, MA
- Patrice Desvigne-Nickens, M.D.
  Medical Officer
  Heart Failure and Arrhythmia Branch
  Division of Cardiovascular Science
  National Heart, Lung, and Blood Institute
  Bethesda, MD
- Douglas S. Diekema, M.D., M.P.H.
  Director of Education, Treuman Katz Center for Pediatric Bioethics
  Seattle Children's Hospital
  Professor of Pediatrics
  Adjunct Assistant Professor, Medical History and Ethics
  University of Washington School of Medicine
  Seattle, WA
- Rachel S. Dokholyan, M.P.H.
  Project Leader
  Duke Clinical Research Institute
  Durham, NC
- Karen Domino, M.D., M.P.H.
  Professor, Department of Anesthesiology and Pain Medicine
  University of Washington
  Seattle, WA
- Wei Dong, M.D., Ph.D.
  Deputy Site Head of Global Product Development in Asia Pacific (AP)
  Head of AP Development Acceleration
  Roche
  Shanghai, China
- Carl Donisi
  Director of Clinical Operations, Physician-Hospital Organization
  Cincinnati Children's Hospital Medical Center
  Cincinnati, OH
- Pamela S. Douglas, M.D., FACC
  Ursula Geller Professor of Research in Cardiovascular Diseases
  Director of Imaging Program at Duke Clinical Research Institute
  Duke University
  Durham, NC
- Nancy A. Dreyer, M.P.H., Ph.D.
  Global Chief of Scientific Affairs
  Senior Vice President
  Real-World & Late Phase Research
  Quintiles
  Cambridge, MA
- Joseph P. Drozda, Jr., M.D., FACC
  Director, Outcomes Research
  Mercy Health
  St. Louis, MO
- Hesha J. Duggirala, Ph.D., M.P.H.
  Epidemiologist
  Food and Drug Administration
  Rockville, MD
- Brenda K. Edwards, Ph.D.
  Associate Director, Surveillance Research Program
  Division of Cancer Control and Population Sciences
  National Cancer Institute
  Bethesda, MD
- Paul Eggers, Ph.D.
  Program Director for Kidney and Urology Epidemiology
  National Institute of Diabetes and Digestive and Kidney Diseases
  Bethesda, MD
- Jonathan S. Einbinder, M.D., M.P.H.
  Brigham and Women's Hospital
  Boston, MA
- Alexander Elbert, Ph.D.
  Director of CF Registry Program
  Cystic Fibrosis Foundation
  Bethesda, MD
- Benjamin C. Eloff, Ph.D.
  Senior Scientific Program Manager
  Division of Epidemiology
  Center for Devices and Radiological Health
  Food and Drug Administration
  Silver Spring, MD
- Dawn Eng, R.N., B.S.N.
  Senior Clinical Trial Head, Oncology Global Medical Affairs
  Novartis Pharmaceuticals Corporation
  East Hanover, NJ
- Sara A. Ephross, PhD
  Director, Worldwide Epidemiology
  GlaxoSmithKline
  Research Triangle Park, NC
- Barbara Evans, J.D., Ph.D.
  Professor of Law
  Co-director, Health Law & Policy Institute
  Director, Center on Biotechnology
  University of Houston Law Center
  Houston, TX
- Efe Eworuke, Ph.D.
  Department of Pharmaceutical Outcomes and Policy
  University of Florida
  Gainesville, FL
- Shamiram Feinglass, M.D., M.P.H.
  Senior Medical Officer
  Coverage and Analysis Group
  Office of Clinical Standards and Quality
  Centers for Medicare & Medicaid Services
  U.S. Public Health Service
  Baltimore, MD
- T. Bruce Ferguson, M.D., FAHA
  Department of Cardiovascular Sciences
  Eastern Carolina University
  Greenville, NC
- Richard Feltbower, Ph.D.
  Senior Lecturer, Division of Epidemiology
  School of Medicine, University of Leeds
  Leeds, United Kingdom
- Stephen E. Fienberg, Ph.D., FRSC
  Maurice Falk University Professor of Statistics and Social Science
  Carnegie Mellon University
  Pittsburgh, PA
- Leslye K. Fitterman, Ph.D.
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Sally Flanzer, Ph.D., CIP
  Regional Program Manager, Child Welfare
  Administration for Children and Families
  Region IX
  San Francisco, CA
  Formerly Human Protections Administrator
  Office of Extramural Research, Education and Priority Populations
  Agency for Healthcare Research and Quality
  Rockville, MD
- Gregg C. Fonarow, M.D.
  Professor of Medicine/Cardiology
  Director, Ahmanson-UCLA Cardiomyopathy Center
  Associate Chief, UCLA Division of Cardiology
  The Eliot Corday Chair in Cardiovascular Medicine and Science
  David Geffen School of Medicine at UCLA
  Los Angeles, CA
- Kathleen M. Fox, Ph.D., M.H.S.
  President
  Strategic Healthcare Solutions, LLC
  Monkton, MD
- Mark J. Fox
  Senior Contract/Grants Administrator
  Compliance Integrity Officer
  American College of Cardiology Foundation
  Washington, DC
- Lori Frank, Ph.D.
  Director of Engagement Research
  Patient-Centered Outcomes Research Institute
  Washington, DC
- Patricia Franklin, M.D., M.B.A., M.P.H.
  Principal Investigator, FORCE TJR
  Professor and Director, Clinical and Outcomes Research
  Department of Orthopedics and Physical Rehabilitation
  University of Massachusetts Medical School
  Worcester, MA
- Sarah Garner, Ph.D., B.Pharm., M.R.Pharm.S.
  Associate Director, Research and Development
  National Institute for Health and Clinical Excellence
  London, United Kingdom
- Yvonne Geissbuehler, Ph.D.
  Senior Clinical Epidemiologist
  Novartis Pharma AG
  Basel, Switzerland
- Eric Gemmen, M.A.
  Senior Director, Biostatistics and Outcomes Research
  Real-World & Late Phase Research
  Quintiles
  Rockville, MD
- Richard E. Gliklich, M.D.
  Leffenfeld Professor Otology/Laryngology, Harvard Medical School
  Principal Investigator, Outcome DEcIDE Center
  President, Real-World & Late Phase Research
  Quintiles
  Cambridge, MA
- Marissa Gordon-Nguyen, J.D.
  Health Information Privacy Specialist
  Office for Civil Rights
  U.S. Department of Health and Human Services
  Washington, D.C.
- Julian M. Goldman, M.D.
  Medical Director, Biomedical Engineering
  Partners HealthCare System
  Attending Anesthesiologist, Massachusetts General Hospital (MGH)
  Director, Program on Medical Device Interoperability, MGH and CIMIT
  Boston, MA
- Melissa M. Goldstein, J.D.
  Associate Professor, Department of Health Policy
  School of Public Health and Health Services
  George Washington University
  Washington, DC
- Julia G. Gorey, J.D.
  Public Health Analyst
  Office for Human Research Protections
  Department of Health and Human Services
  Rockville, MD
- Susan Grandy, Ph.D., M.B.A.
  Global Payer Evidence Director
  Global Medicines Development
  AstraZeneca
  Wilmington, DE
- Robert Greenlee, Ph.D., M.P.H.
  Research Scientist, Epidemiology Research Center
  Marshfield Clinic Research Foundation
  Marshfield, WI
- Marie R. Griffin, M.D., M.P.H.
  Professor of Preventive Medicine
  Professor of Medicine
  Vanderbilt University School of Medicine
  Nashville, TN
- Stephen C. Groft, Pharm.D.
  Director, Office of Rare Diseases Research
  National Institutes of Health
  Bethesda, MD
- Thomas Gross, M.D., M.P.H.
  Director, Office of Surveillance and Biometrics
  Center for Devices and Radiological Health
  Food and Drug Administration
  Rockville, MD
- Claudia Grossmann, Ph.D.
  Senior Program Officer
  Institute of Medicine
  Washington, DC
- Joanna Haas, M.D., M.Sc.
  Vice President, Global Patient Safety and Risk Management
  Genzyme Corporation
  Cambridge, MA
- Rosemarie Hakim, Ph.D.
  Senior Research Advisor
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- John D. Halamka, M.D., M.S.
  Beth Israel Deaconess Medical Center
  Harvard Medical School
  New England Health Electronic Data Interchange Network
  MA-SHARE
  U.S. Healthcare Information Technology Standards Panel
  Boston, MA
- Stephen C. Hammill, M.D.
  Professor of Medicine
  Mayo Clinic College of Medicine
  Director, Electrocardiography Laboratory
  Rochester, MN
- Robert E. Harbaugh, M.D., FAANS, FACS, FAHA
  Director, Penn State Institute of the Neurosciences
  University Distinguished Professor and Chair, Department of Neurosurgery
  Professor, Department of Engineering Science and Mechanics
  Penn State University, M.S. Hershey Medical Center
  Hershey, PA
- Melanie J. Harrison, M.D., M.S.C.E.
  Group Medical Director
  Global Pharmacovigilance and Epidemiology
  Bristol-Myers Squibb
  Pennington, NJ
- Christina M. Heide, J.D.
  Senior Health Information Privacy Policy Specialist
  Office for Civil Rights
  U.S. Department of Health and Human Services
  Washington, DC
- Adrian F. Hernandez, M.D., M.H.S.
  Associate Professor of Medicine
  Duke University School of Medicine
  Durham, NC
- Sonia Hernández-Díaz, M.D., M.P.H., Dr.P.H.
  Associate Professor of Epidemiology
  Director, Pharmacoepidemiology Program
  Harvard School of Public Health
  Boston, MA
- Kathleen Hewitt, M.S.N., R.N., A.A.C.C., CPHQ
  Associate Vice President
  American College of Cardiology
  Washington, DC
- Janet Hiller, M.P.H., Ph.D.
  Professor of Public Health
  Director, Adelaide Health Technology Assessment
  University of Adelaide
  Adelaide, Australia
- D. Kevin Horton, Dr.P.H., M.S.P.H.
  Chief
  Environmental Health Surveillance Branch
  Agency for Toxic Substances & Disease Registry
  Centers for Disease Control and Prevention
  Atlanta, GA
- Holly L. Howe, Ph.D.
  Executive Director
  North American Association of Central Cancer Registries, Inc.
  Springfield, IL
- Jenifer Hughes, Med.I.T.
  Senior Vice President, Administrative Network, Inc.
  Oakland Southfield Physicians, PC
  Southfield, MI
- Keith M. Hume, M.A.
  Vice President, Research & Scientific Affairs
  American Society of Plastic Surgeons
  Chief Operating Officer
  The Plastic Surgery Foundation
  Arlington Heights, IL
- Barrie J. Hurwitz, M.B., MRCP
  Associate Professor Emeritus of Neurology and Community and Family Medicine
  Duke University Medical Center
  Durham, NC
- Michael Ibara, Pharm.D.
  Head of Pharmacovigilance Information Management
  Pfizer, Inc.
  New York, NY
- Waguih William IsHak, M.D., FAPA
  Director, Psychiatry Residency Training and Medical Student Education
  Consultant Psychiatrist, Consultation-Liaison Service
  Cedars-Sinai Medical Center
  Clinical Professor of Psychiatry
  University of California Los Angeles
  Los Angeles, CA
- Maria Inacio, M.S.
  Epidemiologist
  Surgical Outcomes and Analysis
  Kaiser Permanente
  San Diego, CA
- Lianna Ishihara
  Manager, Worldwide Epidemiology
  GlaxoSmithKline
  Stockley Park, United Kingdom
- Solomon Iyasu, M.D., M.P.H.
  Director
  Division of Epidemiology
  Office of Surveillance and Epidemiology
  Center for Drug Evaluation and Research
  Food and Drug Administration
  Silver Spring, MD
- Nat Jackson, M.S.
  Project Manager
  Kaiser Permanente Colorado Institute for Health Research
  Denver, CO
- Emma James, Ph.D.
  Associate Director, Medical Affairs and Global Registries
  Synageva BioPharma Corp.
  Lexington, MA
- Robert A. Jenders, M.D., M.S., FACP, FACMI
  Co-Director, Center for Biomedical Informatics
  Professor of Medicine, Charles Drew University
  Professor, David Geffen School of Medicine
  University of California, Los Angeles
  Los Angeles, CA
- Ani John, B.S.N., M.P.H.
  Head of Immunology Registries
  Genentech, Inc. a member of the Roche Group
  South San Francisco, CA
- Peter I. Juhn, M.D., M.P.H.
  President
  Therapeutic Resource Centers
  Medco Health Solutions, Inc.
  Franklin Lakes, NJ
- Pam Kadlubek, M.P.H.
  Assistant Director, Quality Oncology Practice Initiative Operations
  American Society of Clinical Oncology
  Alexandria, VA
- Michael Kahn, M.D., Ph.D.
  Associate Professor of Epidemiology, Department of Pediatrics
  University of Colorado Denver
  Co-Director and Biomedical Informatics Core Director
  Colorado Clinical and Translational Sciences Institute
  Director of Clinical Informatics, Department of Quality & Patient Safety
  Children's Hospital Colorado
  Aurora, CO
- Moira K. Kapral, M.D., M.Sc., FRCPC
  Associate Professor of Medicine, University of Toronto
  Senior Scientist, Institute for Clinical Evaluative Sciences
  Ontario, Canada
- Alan F. Karr, Ph.D.
  Director
  National Institute of Statistical Sciences
  Research Triangle Park, NC
- Michael Karukin, P.A., Ph.D.
  Director, Registries
  Teva Pharmaceuticals USA
  Miami, FL
- Irene Katzan, M.D., M.S.
  Director, Neurological Institute Center for Outcomes Research & Evaluation
  Cleveland Clinic Foundation
  Center for Health Care Research & Policy, MetroHealth Medical Center
  Cleveland, OH
- David W. Kaufman, Sc.D.
  Associate Director, Slone Epidemiology Center
  Professor of Epidemiology, Boston University School of Public Health
  Boston, MA
- Laura Khurana, M.P.H.
  Formerly Research Associate
  Real-World & Late Phase Research
  Quintiles
  Cambridge, MA
- Shukri F. Khuri, M.D. (deceased)
  Professor of Surgery, Harvard Medical School
  Co-Founder, National Surgical Quality Improvement Program
  VA Boston Healthcare System
  West Roxbury, MA
- Stuart Kim, J.D., M.S.
  Associate General Counsel, Regulatory Affairs
  Covidien
  Hazelwood, MO
- James K. Kirklin, M.D.
  Professor and Director, Division of Cardiothoracic Surgery
  University of Alabama at Birmingham
  Birmingham, AL
- Emily A. Knapp
  Patient Registry Senior Coordinator
  Cystic Fibrosis Foundation
  Bethesda, MD
- Clifford Ko, M.D.
  Professor, Department of Surgery
  Director, Center for Surgical Outcomes and Quality
  University of California, Los Angeles
  Los Angeles, CA
- Catherine Koepper
  Director, Global Registry Program
  Genzyme, a Sanofi company
  Cambridge, MA
- Prof Dr. Stefan Kölker
  Head, Division of Inherited Metabolic Diseases
  Centre for Paediatric and Adolescent Medicine
  University of Heidelberg
  Heidelberg, Germany
- Barbara Konkle, M.D.
  Director, Clinical and Translational Research
  Medical Director, Hemostasis Reference Laboratory
  Puget Sound Blood Center
  Professor of Medicine/Hematology
  University of Washington
  Seattle, WA
- Joel M. Kremer, M.D.
  Pfaff Family Professor of Medicine
  Albany Medical College
  Director of Research
  The Center for Rheumatology
  President
  The Consortium for Rheumatology Researchers of North America
  Albany, NY
- Harlan M. Krumholz, M.D., S.M.
  Harold H. Hines, Jr. Professor of Medicine and Epidemiology and Public Health
  Director, Robert Wood Johnson Clinical Scholars Program
  Yale University School of Medicine
  Director, Center for Outcomes Research and Evaluation
  Yale-New Haven Hospital
  New Haven, CT
- Kimary Kulig, Ph.D., M.P.H.
  Group Director, Oncology Collaborative Institute
  Bristol-Myers Squibb
  Plainsboro, NJ
- Richard E. Kuntz, M.D., M.Sc.
  Senior Vice President and Chief Scientific, Clinical and Regulatory Officer
  Medtronic, Inc.
  Minneapolis, MN
- Rebecca D. Kush, Ph.D.
  President and CEO
  Clinical Data Interchange Standards Consortium
  Austin, TX
- Kenneth A. LaBresh, M.D.
  Senior Fellow
  RTI International
  Waltham, MA
- Joseph A. Ladapo, M.D., Ph.D.
  Beth Israel Deaconess Medical Center
  Boston, MA
- Julia I. Lane
  National Science Foundation
  Washington, DC
- Debra R. Lappin, J.D.
  Senior Vice President
  B&D Consulting LLC – Health and Life Sciences Practice
  Washington, D.C.
- Timothy L. Lash, D.Sc., M.P.H.
  Professor, Epidemiology
  Rollins School of Public Health
  Emory University
  Atlanta, GA
- Michelle Bertagna Leavy, M.P.H.
  Manager, Health Policy
  Real-World & Late Phase Research
  Quintiles
  Cambridge, MA
- Erwan Muros Le Rouzic, M.P.H.
  Senior Epidemiologist
  Actelion Pharmaceuticals Ltd
  Allschwil, Switzerland
- Marc C. Levesque, M.D., Ph.D.
  Associate Professor, Division of Rheumatology and Clinical Immunology
  University of Pittsburgh
  Pittsburgh, PA
- Daniel Levy, M.S.
  Chief Technology Officer
  Real-World & Late Phase Research
  Quintiles
  Cambridge, MA
- Barbara Lippe, M.D.
  Principal Medical Director
  Genentech, Inc.
  South San Francisco, CA
- Wendy Lipworth, M.D., Ph.D.
  Postdoctoral Research Fellow, Centre for Clinical Governance Research in Health
  Australian Institute of Health Innovation
  Faculty of Medicine
  University of New South Wales
  Sydney, Australia
- Peter Littlejohns, M.D.
  Clinical and Public Health Director
  National Institute for Health and Clinical Excellence
  London, UK
- Rebecca Love, M.P.H., R.N.
  Project Manager, Surgical Outcomes and Analysis
  Southern California Permanente Medical Group
  San Diego, CA
- Flora Lum, M.D.
  Executive Director
  H. Dunbar Hoskins Jr, MD Center for Quality Eye Care
  Director, Quality of Care & Knowledge Base Development
  American Academy of Ophthalmology
  San Francisco, CA
- Theodore Lystig, Ph.D.
  Lead Corporate Biostatistician
  Medtronic
  Minneapolis, MN
- Christina DeFilippo Mack, Ph.D., M.S.P.H.
  Research Consultant
  Real-World & Late Phase Research
  Quintiles
  Cambridge, MA
- Jonathon Maguire, M.D., M.Sc., FRCPC
  Paediatrician and Scientist, Li Ka Shing Knowledge Institute
  Department of Pediatrics
  St. Michael's Hospital
  Toronto, Canada
- David J. Malenka, M.D.
  Professor of Medicine, The Geisel School of Medicine at Dartmouth
  The Dartmouth Institute for Health Policy and Clinical Practice
  Hanover, NH
  Section of Cardiology
  Dartmouth-Hitchcock Medical Center
  Lebanon, NH
- Gregory B. Maletis, M.D.
  Chief of Orthopedics
  Baldwin Park Medical Center
  Kaiser Permanente
  Baldwin Park, CA
- Bradley Malin, Ph.D.
  Associate Professor
  Vanderbilt University
  Nashville, TN
- Ann Mallard, M.P.H.
  Formerly Associate Director, Registries and Health Outcomes
  Kendle International Inc.
  Wilmington, NC
- Keith Mandel, M.D.
  Vice President of Medical Affairs, Physician Hospital Organization
  James M. Anderson Center for Health Systems Excellence
  Cincinnati Children's Hospital Medical Center
  Cincinnati, OH
- Neal Mantick, M.S.
  Senior Director, Observational Research
  PAREXEL International
  Boston, MA
- Danica Marinac-Dabic, M.D., Ph.D.
  Director, Division of Epidemiology
  Center for Devices and Radiological Health
  Food and Drug Administration
  Silver Spring, MD
- Bruce C. Marshall, M.D.
  Vice President of Clinical Affairs
  Cystic Fibrosis Foundation
  Bethesda, MD
- Frederick Masoudi, M.D., M.S.P.H.
  Associate Professor of Medicine
  Division of Cardiology
  University of Colorado Anschutz Medical Campus
  Aurora, CO
- David Matchar, M.D.
  Professor of Medicine
  Duke University Medical Center
  Durham, NC
  Professor and Director
  Health Services and Systems Research
  Duke-NUS Graduate Medical School
  Singapore
- Pattra Mattox, S.M.
  Associate Epidemiologist
  Real-World & Late Phase Research
  Quintiles
  Cambridge, MA
- Vandana Menon, M.D.
  Formerly Director of Clinical Epidemiology
  Real-World & Late Phase Research
  Quintiles
  Cambridge, MA
- Susan McAndrew, J.D.
  Deputy Director for Health Information Privacy
  Office for Civil Rights
  U.S. Department of Health and Human Services
  Washington, D.C.
- C. Geoffrey McDonough
  Vice President, Global Medical Affairs
  Genzyme Therapeutics
  Cambridge, MA
- Newell McElwee, Pharm.D., M.S.P.H.
  Senior Director/Team Leader
  Global Outcomes Research
  Pfizer, Inc.
  New York, NY
- J. Michael McGinnis, M.D., M.P.P.
  Senior Scholar
  Institute of Medicine
  National Academy of Sciences
  Washington, DC
- Deven McGraw, J.D., M.P.H., L.L.M.
  Director, Health Privacy Project
  The Center for Democracy and Technology
  Washington, DC
- Charles R. McKay, M.D., FACC
  Professor of Medicine, Chief, Division of Cardiology
  Los Angeles Biomedical Research Institute at Harbor-UCLA Medical Center
  Torrance, CA
- R. Scott McKenzie, M.D.
  Senior Director, Translational Science Team
  Health Economics & Outcomes Research
  Janssen Scientific Affairs
  Dallas, TX
- Patricia McKinney, Ph.D.
  Emeritus Professor of Paediatric Epidemiology Division of Epidemiology
  School of Medicine
  University of Leeds
  Leeds, United Kingdom
- Magda Nunes de Melo, B.Sc.Pharm., M.Sc.
  Manager, Observational Epidemiology and Qualitative Research Unit
  Applied Health Research Centre
  St. Michael's Hospital
  Toronto, Canada
- Aaron B. Mendelsohn, Ph.D., M.P.H.
  Director of Epidemiology
  Real-World & Late Phase Research
  Quintiles
  Rockville, MD
- Marissa A. Miller, D.V.M., M.P.H.
  Branch Chief, Advanced Technologies and Surgery
  National Heart, Lung, and Blood Institute
  National Institutes of Health
  Bethesda, MD
- Benjamin Miriovsky, M.D.
  Fellow, Hematology-Oncology
  Duke University School of Medicine
  Durham, NC
- Barry Mirrer, M.S., CMQ/OE
  Senior Director, Quality Assurance
  Real-World & Late Phase Research
  Quintiles
  Cambridge, MA
- Kristi R. Mitchell, M.P.H.
  Formerly Senior Director, Research, Development, and Quality Products
  American College of Cardiology
  Washington, DC
- Jen Moore
  Senior Director, Operations
  MMC Physician-Hospital Organization
  Portland, ME
- Louise Morgan, M.S.N., CPHQ
  National Director, Get With The Guidelines
  American Heart Association
  Scotch Plains, NJ
- Anne Morris, Ph.D.
  Formerly Associate Registry Epidemiologist
  Genentech, Inc.
  South San Francisco, CA
- Lawrence H. Muhlbaier, Ph.D.
  Associate Professor, Biostatistics and Bioinformatics
  Duke University School of Medicine
  Durham, NC
- Oleg Muravov, M.D., Ph.D.
  Medical Epidemiologist
  Agency for Toxic Substances & Disease Registry/Centers for Disease Control and Prevention
  Atlanta, GA
- Barbara Muth
  Formerly Director of Research and Guidelines
  American Society for Radiation Oncology
  Washington, DC
- David C. Naftel, Ph.D.
  Professor of Surgery, Division of Cardiothoracic Surgery
  Professor of Biostatistics, School of Public Health
  University of Alabama at Birmingham
  Birmingham, AL
- Steven E. Nissen, M.D.
  Chairman, Department of Cardiovascular Medicine
  Cleveland Clinic
  Cleveland, OH
- Luigi Naldi, M.D.
  Director, Centro Studi GISED
  Dermatologist, Department of Dermatology
  Azienda Ospedaliera papa Giovanni XXIII
  Bergamo, Italy
- Sharon-Lise T. Normand, Ph.D.
  Professor, Department of Health Care Policy
  Harvard Medical School
  Professor, Department of Biostatistics
  Harvard School of Public Health
  Boston, MA
- J. Marc Overhage, M.D., Ph.D.
  Chief Medical Informatics Officer
  Siemens Healthcare
  Malvern, PA
- Dimitrios Pappas, M.D., M.P.H.
  Assistant Professor of Medicine
  Columbia University College of Physicians and Surgeons
  Scientific Director
  The Consortium for Rheumatology Researchers of North America
  New York, NY
- Samantha Parker
  Director of External Affairs and Rare Disease Partnerships
  Orphan Europe Recordati Group
  Paris, France
- Patricia Parkin, M.D., FRCPC
  Research Director
  Division of Pediatric Medicine and the Pediatric Outcomes Research Team
  The Hospital for Sick Children
  Toronto, Canada
- Alexandra Parnell, M.S.
  Research Associate
  Real-World & Late Phase Research
  Quintiles
  Cambridge, MA
- Gareth Parry, Ph.D.
  Director, Quality Measurement & Analysis
  Department of Medicine
  Children's Hospital
  Boston, MA
- Roger Parslow, Ph.D.
  Senior Lecturer, Division of Epidemiology
  School of Medicine
  University of Leeds
  Leeds, United Kingdom
- Hannah Patrick
  Consultant Clinical Advisor to the IP Programme
  National Institute for Health and Clinical Excellence
  London, United Kingdom
- Elizabeth Paxton, M.A.
  Director, Kaiser Permanente National Implant Registries
  Southern California Permanente Medical Group
  San Diego, CA
- Steven Pearson, M.D.
  Associate Professor of Ambulatory Care and Prevention
  Harvard Medical School
  Boston, MA
- Eric Peterson, M.D., M.P.H.
  Fred Cobb, M.D., Distinguished Professor of Cardiology
  Duke University Medical Center
  Director, Duke Clinical Research Institute
  Durham, NC
- Kristofer M. Petren
  Patient Registry Specialist
  Cystic Fibrosis Foundation
  Bethesda, MD
- Steve E. Phurrough, M.D., M.P.A.
  Medical Officer
  Agency for Healthcare Research and Quality
  Rockville, MD
- Richard Platt, M.D., M.Sc.
  Professor and Chair, Department of Population Medicine
  Harvard Medical School and Harvard Pilgrim Health Care Institute
  Boston, MA
- Karen L. Posner, Ph.D.
  Research Professor, Department of Anesthesiology and Pain Medicine
  University of Washington
  Seattle, WA
- Richard L. Prager, M.D.
  Professor, Cardiac Surgery
  Head, Section of Adult Cardiac Surgery
  Director, Cardiovascular Center
  University of Michigan Health System
  Ann Arbor, MI
- Victoria M. Prescott, J.D.
  CEO
  McBroom Consulting, LLC
  Tampa, FL
- Michael T. Rapp, M.D., J.D., FACEP
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Robert Reynolds, Sc.D.
  Senior Director, Global Head, Epidemiology Safety and Risk Management
  Pfizer, Inc.
  New York, NY
- Janice A. Richards, R.N., B.A.
  Formerly Project Manager
  Registry of the Canadian Stroke Network
  Toronto, Ontario, Canada
- Karen Richards
  Administrative Director, Research and Optimal Patient Care
  American College of Surgeons
  Chicago, IL
- Rachel L. Richesson, Ph.D., M.P.H.
  Associate Professor
  Duke University
  Durham, NC
- Gerald F. Riley, M.S.P.H.
  Social Science Research Analyst
  Office of Research, Development, and Information
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Susan Sinclair Roberts, Ph.D.
  Associate Professor, Clinical Research Program
  University of North Carolina Wilmington
  Senior Advisor
  INC Research
  Wilmington, NC
- Nicole Robichaud
  Formerly Principal Project Manager, Gaucher Registry
  Genzyme, a Sanofi company
  Cambridge, MA
- Sara Rosenbaum, J.D.
  Harold and Jane Hirsh Professor, Health Law and Policy
  The George Washington University
  School of Public Health and Health Services
  Washington, DC
- Daniel Rosenberg, Ph.D., M.P.H.
  Senior Director, Head Epidemiology & Observational Studies
  Actelion Pharmaceuticals Ltd
  Allschwil, Switzerland
- Kenneth J. Rothman, Dr.P.H.
  Vice President, Epidemiology Research
  RTI Health Solutions
  Research Triangle Park, NC
- Koryn Y. Rubin
  Senior Manager, Quality Improvement
  American Association of Neurological Surgeons/Congress of Neurological Surgeons
  Washington, DC
- Yaffa Rubinstein, Ph.D.
  Director of Patient Resources for Clinical and Translational Research
  Office of Rare Diseases Research
  National Center for Advancing Translational Sciences
  National Institutes of Health
  Bethesda, MD
- Patricia Russo, Ph.D.
  Vice President, Integrated Analytic Services
  Real-World & Late Phase Research
  Quintiles
  Rockville, MD
- Susan T. Sacks, Ph.D.
  Director, Epidemiology
  Roche Biometrics
  Nutley, NJ
- Gregory Samsa, Ph.D.
  Associate Professor, Department of Biostatistics and Bioinformatics
  Duke University School of Medicine
  Durham, NC
- Gillian D. Sanders, Ph.D.
  Director, Duke Evidence-based Practice Center
  Associate Professor of Medicine
  Duke Clinical Research Institute
  Durham, NC
- Sheri Sanders, M.B.A., B.S.N., R.N.
  Vice President, Registry and Biorepository Services
  Caris Life Sciences
  Phoenix, AZ
- Grannum Sant, M.D., FRCS, FACS
  Vice President and Interim Head
  Oncology Medical Unit
  Head of Urology Portfolio
  Sanofi-aventis U.S.
  Bridgewater, NJ
  Adjunct Professor of Urology, Tufts University School of Medicine
  Boston, MA
- Brian C. Sauer, Ph.D., M.S.
  Assistant Professor, Internal Medicine
  Adjunct Assistant Professor, Pharmacotherapy and Family and Preventive Medicine
  University of Utah School of Medicine
  Salt Lake City, UT
- William B. Saunders, Ph.D., M.P.H.
  Manager, Research & Analytics
  GE Medical
  Charlotte, NC
- Juergen Schmider M.D., Ph.D.
  Corporate Safety Officer and Vice President, Global Pharmacovigilance & Epidemiology
  Cephalon, Inc.
  Frazer, PA
- Peter Schmidt, Ph.D.
  CIO and Vice President of Programs
  National Parkinson Foundation
  Miami, FL
- Wendy Schroeder, R.N., B.S.N., CCRC, CRCP, CHRC
  Formerly Senior Director, Registry and Biorepository Network Management
  Caris Life Sciences
  Phoenix, AZ
- Lee H. Schwamm, M.D., FAHA
  Executive Vice Chairman, Department of Neurology
  C. Miller Fisher Endowed Chair
  Director, MGH Stroke Services
  Massachusetts General Hospital
  Professor of Neurology
  Harvard Medical School
  Boston, MA
- Barbara Schwierin, Ph.D.
  Associate Director, Observational Studies
  Actelion Pharmaceuticals, Ltd.
  Allschwil, Switzerland
- Art Sedrakyan, M.D., Ph.D.
  Associate Professor
  Director, Patient-Centered Comparative Effectiveness Program and MDEpiNet Science and Infrastructure Center
  Weill Cornell Medical College and
  New York-Presbyterian Hospital
  New York, NY
- David M. Shahian, M.D.
  Vice President, Center for Quality and Safety
  Massachusetts General Hospital
  Professor of Surgery, Harvard Medical School
  Boston, MA
- Neha Sheth, Pharm.D.
  Executive Director, Risk Management Strategy & Pharmacoepidemiology
  Product Safety Pharmacovigilance
  Astellas Pharma Global Development
  Northbrook, IL
- Christopher Simmons, B.S., B.A.
  Clinical Research and Database Program Associate
  American Society of Plastic Surgeons
  Arlington Heights, IL
- Kumar Sivaraman
  Director of Product Strategy, Health Sciences Global Business Unit
  Oracle
  Los Angeles, CA
- James G. Snell, J.D.
  Co-chair, Intellectual Property Group and Privacy and Security Group
  Bingham McCutchen, LLP
  Palo Alto, CA
- Rachel Sobel, Dr.P.H.
  Senior Director, Epidemiology
  Pfizer
  New York, NY
- Henrik Toft Sørensen, M.D., Ph.D., Dr.Med.Sci.
  Professor, Chair
  Department of Clinical Epidemiology
  Aarhus University Hospital
  Aarhus, Denmark
- John Spertus, M.D., M.P.H., FACC, FAHA
  Deputy Editor, Circulation: Cardiovascular Quality and Outcomes Research
  Professor, University of Missouri – Kansas City
  Clinical Director of Outcomes Research
  Mid America Heart Institute of Saint Luke's Hospital
  Kansas City, MO
- Judy A. Staffa, Ph.D., R.Ph.
  Director, Division of Epidemiology II
  Office of Surveillance & Epidemiology
  Center for Drug Evaluation & Research
  Food and Drug Administration
  Silver Spring, MD
- Paul Stang, Ph.D.
  Senior Director: Epidemiology
  Janssen Research & Development, LLC / Johnson & Johnson
  Titusville, NJ
- Kathryn Starzyk, Sc.M.
  Director, Epidemiology
  Real-World & Late Phase Research
  Quintiles
  Cambridge, MA
- Charlie Strange, M.D.
  Professor of Pulmonary, Critical Care, Allergy, and Sleep Medicine
  Medical University of South Carolina
  Charleston, SC
- Walter L. Straus, M.D., M.P.H.
  Global Director for Scientific Affairs - Vaccines
  Merck Research Laboratories
  Adjunct Scholar, Center for Clinical Epidemiology and Biostatistics
  University of Pennsylvania School of Medicine
  Upper Gwynedd, PA
- Edna Stoehr
  Global Study Manager
  Genentech, Inc.
  South San Francisco, CA
- Marshall Summar, M.D.
  Division Chief, Genetics and Metabolism
  Children's National Medical Center
  Professor, Pediatrics
  George Washington University School of Medicine and Health Sciences
  Washington, DC
- Elizabeth J. Swain
  Director of Pharmacovigilance Advocacy and Policy
  Global Clinical Safety and Pharmacovigilance
  GlaxoSmithKline
  Stevenage, United Kingdom
- Deborah Symmons, M.D.
  Professor of Rheumatology and Musculoskeletal Epidemiology
  University of Manchester
  Manchester, United Kingdom
- Michelle Tarver, M.D., Ph.D.
  Medical Officer/Epidemiologist
  Center for Devices and Radiological Health
  Food and Drug Administration
  Silver Spring, MD
- Melissa S. Tassinari, Ph.D.
  Senior Clinical Advisor, Pediatric and Maternal Health Staff
  Office of New Drugs
  Center for Drug Evaluation and Research
  Food and Drug Administration
  Silver Spring, MD
- Dale R. Tavris, M.D., M.P.H.
  Medical Officer/Epidemiologist
  Center for Devices and Radiological Health
  Food and Drug Administration
  Silver Spring, MD
- Michael D. Taylor, Pharm.D., Ph.D.
  Global Head of Epidemiology for Oncology
  Genentech, A Member of the Roche Group
  South San Francisco, CA
- Joseph Terdiman, M.D., Ph.D.
  Formerly Director of Information Technology
  Division of Research
  Kaiser Permanente
  Oakland, CA
- Jane Hyatt Thorpe, J.D.
  Associate Professor, School of Public Health and Health Services
  Director, Healthcare Corporate Compliance Program
  The George Washington University
  Washington, DC
- Hugh Tilson, M.D., M.P.H., Dr.P.H.
  Adjunct Professor, Public Health Leadership
  University of North Carolina Gillings School of Global Public Health
  Chapel Hill, NC
- Stephen Toovey, M.D., Ph.D.
  Chief Medical Officer
  d3 Ltd
  Hong Kong, China
- Anne E. Trontell, M.D., M.P.H.
  Program Director, Centers for Education and Research on Therapeutics
  Center for Outcomes and Evidence
  Agency for Healthcare Research and Quality
  Rockville, MD
- Kelly Trout, B.S.N., R.N.
  International WAGR Syndrome Association
  San Antonio, TX
- Donald C. Tyler, M.D., M.B.A.
  Executive Director, Wake Up Safe
  Society for Pediatric Anesthesia
  Richmond, VA
- Jack V. Tu, M.D., Ph.D.
  Professor of Medicine, University of Toronto
  Staff Physician, Sunnybrook Schulich Heart Centre
  Senior Scientist, Institute for Clinical Evaluative Sciences
  Ontario, Canada
- Marlous Van Laar, M.Sc.
  Research Statistician, Division of Epidemiology
  School of Medicine
  University of Leeds
  Leeds, United Kingdom
- Paul D. Varosy, M.D.
  Director of Cardiac Electrophysiology
  VA Eastern Colorado Health Care System
  Associate Professor of Medicine
  University of Colorado Denver
  Denver, CO
- Priscilla Velentgas, Ph.D.
  Senior Director of Epidemiology
  Real-World & Late Phase Research
  Quintiles
  Cambridge, MA
- Lisa Griffin Vincent, M.A., Ph.D.
  Chief Regulatory Officer and President, Outcomes Research Solutions
  PatientPoint
  Chicago, IL
- Jeffrey Wagener, M.D.
  Professor of Pediatrics
  University of Colorado Medical School
  Aurora, CO
- Cunlin Wang, M.D., Ph.D.
  Medical Epidemiologist, Center for Device and Radiological Health
  Food and Drug Administration
  Silver Spring, MD
  Assistant Professor
  Johns Hopkins Medical Institutions
  Baltimore, MD
- Roshanthi Weerasinghe, M.P.H.
  Research Associate, Providence Regional Breast Health Registry
  Providence Cancer Center
  Portland, OR
- Christopher Weiser, J.D., M.P.H.
  Health Insurance Specialist
  Centers for Medicare and Medicaid Services
  Washington, DC
- Jennifer Weisman, Ph.D.
  Staff Scientist
  Strategic Analysis, Inc.
  Arlington, VA
- Suzanne L. West, M.P.H, Ph.D.
  Health, Social, and Economics Research
  RTI International
  Research Triangle Park, NC
- David S. Wendler, M.A., Ph.D.
  Head, Unit on Vulnerable Populations Department of Bioethics
  National Institutes of Health Clinical Center
  Bethesda, MD
- Marcy Wilder, J.D.
  Partner
  Hogan & Hartson LLP
  Washington, DC
- Marcus D. Wilson, Pharm.D.
  President
  HealthCore
  Wilmington, DE
- Almut Winterstein, Ph.D.
  Professor, Department of Pharmaceutical Outcomes and Policy
  University of Florida
  Gainesville, FL
- Randy Woodward
  Formerly Senior Application Developer
  Division of Emergency Medicine, Center for Simulation and Research
  Cincinnati Children's Hospital Medical Center
  Cincinnati, OH
- Albert Wu, M.D., M.P.H.
  Professor of Health Policy and Management
  Director, Center for Health Services and Outcomes Research
  Johns Hopkins Bloomberg School of Public Health
  Baltimore, MD
- John Yee, M.D., M.P.H.
  Formerly Vice President, US and Global Medical Affairs
  Genzyme, a Sanofi company
  Cambridge, MA
- Marianne Ulcickas Yood, D.Sc., M.P.H.
  Principal Epidemiologist, EpiSource
  Hamden, CT
  Associate Research Scientist, Epidemiology and Public Health, Yale University School of Medicine
  New Haven, CT