# Evaluating Registries

14 Assessing Quality