# Operating Registries

9 Recruiting and Retaining Participants in the Registry

10 Data Collection and Quality Assurance

11 Interfacing Registries With Electronic Health Records

12 Adverse Event Detection, Processing, and Reporting

13 Analysis and Interpretation of Registry Data To Evaluate Outcomes